# Methods

## Evidence Gaps

The authors of the CER1 identified several topics with little or no evidence on which to base conclusions. As part of the FRN identification and prioritization process, we developed a preliminary list of evidence gaps (Appendix B) based on SOE and other information gleaned from the results and limitations sections of the CER. Our main focus was on capturing topics with insufficient information. We then applied the PICOTS from the CER1 inclusion/exclusion criteria and developed an analytic framework (Figure 1).

## Identification of Stakeholders

We identified a broad range of potential stakeholders in consultation with our AHRQ Task Order Officer and during an internal planning meeting to which we invited representatives from the EPC that produced the draft review. During the meeting, we discussed potential stakeholders known to the experts on our team; we also asked the CER authors for names of stakeholders that they had used in generating the CER. Each potential stakeholder completed a statement of disclosure regarding conflicts of interest and had to be approved for participation by AHRQ prior to the first stakeholder call.

We sought a variety of individuals who represented one or more perspectives, including patient and family advocacy groups; health care providers, including diagnosticians and treatment experts; educators of preschool and school-age children; researchers, including those with experience in pharmacology, psychiatry, education, epidemiology, and screening tools; state policymakers and payers of services; professional provider and educator organizations; individuals with knowledge of health services delivery systems; and research funders. Some individuals could represent more than one stakeholder group. Our purpose in seeking these different perspectives was to produce a group that represented varied points of view on issues related to the use of FGAs and SGAs in pediatric and young adult populations.

We invited 17 individuals and organizations to participate in the stakeholder group. To ensure the inclusion of specific perspectives, we asked invited individuals who were not able to participate to refer us to someone else from their agency or organization. We provided potential stakeholders with a brief description of the project, including their role and the amount of time we expected them to contribute. Twelve stakeholders accepted our invitation.

## Identification of Evidence Gaps

Throughout this report, the terms “evidence gap,” “research question,” and “research need” are defined as follows: Evidence gap is a gap in the CER that limited the ability to make conclusions on the questions asked. Research question is a statement of the purpose of a study. Research need is the top tier of prioritized evidence gaps identified through stakeholder engagement. Our process for identifying and prioritizing FRNs is shown in Appendix C.

After identifying the preliminary list of evidence gaps from the CER,1 we presented the list (Appendix B) to the stakeholders as part of their orientation materials. During the first call, we invited stakeholders to comment on and make contributions to the list of evidence gaps. Project investigators revised the list of evidence gaps after receiving stakeholder input and applied the PICOTS elements to the new and revised gaps to ensure that each gap addressed one or more PICOTS elements and was within the scope of the CER.

## Criteria for Prioritization

After the stakeholders had an opportunity to review, discuss, and revise the list of evidence gaps, we asked them to prioritize the gaps using specific criteria. The criteria included their own perspectives and the interests of their constituents along with the following criteria adapted from the Effective Health Care (EHC) Program Selection Criteria (Appendix D): importance, desirability of new research/duplication, and impact (Table 1). The proposed prioritization criteria emphasized the elements that were most applicable to stakeholders considering FRNs on a topic already under review by the EHC. We did not ask the stakeholders to consider the other two elements of the EHC Program Selection Criteria, appropriateness and feasibility, at this juncture.

Table 1 Suggested prioritization criteria, adapted from the AHRQ EHC Program Selection Criteria

Importance | Represents a significant disease burden; large proportion or priority population
Importance | Is of high public interest; affects health care decision making, outcomes, or costs for a large proportion of the US population or for a priority population in particular
Importance | Represents important uncertainty for decision makers
Importance | Incorporates issues around both clinical benefits and potential clinical harms
Importance | Represents important variation in clinical care, or controversy in what constitutes appropriate clinical care
Importance | Represents high costs due to common use, to high unit costs, or to high associated costs to consumers, to patients, to health care systems, or to payers
Desirability of New Research/Duplication | Would not be redundant (the proposed topic is not already covered by available or soon-to-be available high-quality systematic review by AHRQ or others)
Potential Impact | Potential for significant health impact, significant economic impact, potential change, potential risk from inaction, addressing inequities and vulnerable populations, and/or addressing a topic with clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups.

Before the prioritization exercise, the project team prepared a list of ongoing studies for the stakeholders. The purpose of this list was to help the stakeholders identify any potential evidence gaps that might be addressed by current research and to use that information to consider whether new research would be duplicative. We developed the list by reviewing titles and short descriptions of research studies obtained through searching online research registries. We searched clinicaltrials.gov, HSRProj, NIH RePORTER, and the International Clinical Trials Registry Project (ICTRP) to find relevant ongoing or recently completed research. Search strategies and the list of ongoing studies presented to the stakeholders are shown in Appendix E. Two people from the research team independently reviewed each ongoing study title and abstract and applied the inclusion and exclusion criteria from the draft review to determine which studies might have met the inclusion criteria for the CER if they had been completed and published results before the CER cutoff date. During the first stakeholder call, the stakeholders reviewed the list of ongoing studies and provided feedback on its completeness and the relevance of the research studies to the existing evidence gaps.

## Engagement of Stakeholders, Researchers, and Funders

The stakeholders contributed to this FRN project via email, conference calls, and Web-based prioritization activities. We planned two conference calls using Go To Meeting^®^ and two rounds of a Web-based prioritization exercise (Appendix F) with the stakeholder group. Prior to the first call, we sent orientation materials to the stakeholders. These materials included the executive summary of the draft review and a description of the FRN project and its goals. Stakeholders also received a meeting packet that included the preliminary list of evidence gaps, the modified EHC Program Selection Criteria, and a list of ongoing studies that were reviewed to determine if they met the inclusion criteria for the review.

After the first and second conference calls, we accepted comments and edits via email from the stakeholders on the list of evidence gaps and PICOTS documents that were discussed during the respective calls. These comments were reflected in changes to the pertinent documents and reflected in the meeting summaries.

Between the first and second calls, we asked the stakeholders to prioritize the revised list of evidence gaps. This was the first round of prioritization, and it was based on the complete list of initial evidence gaps. The second round of prioritization occurred after the second call and consisted of only the top-tier evidence gaps (i.e. those that were ranked the highest in the first round). The Web-based prioritization exercises allowed each stakeholder to distribute a limited number of star-shaped indicators (referred to as stars in the remainder of this document) to those they viewed as the highest-priority gaps. In the first round, we gave each stakeholder a total of eight stars, which they could distribute among 14 evidence gaps. In the second round, the stakeholders received eight stars to distribute among eight evidence gaps. In both rounds, a single person could place up to three stars on any one gap.

Prior to the second call, we sent the stakeholders the results of the first online prioritization exercise. For the upper-tier, or highest-ranking, evidence gaps, we also shared the draft PICOTS. During the second call, we reviewed and discussed the results of the prioritization exercise and asked stakeholders for feedback on the PICOTS and for any thoughts on potential research designs for the upper-tier evidence gaps. Following this discussion, we applied the updated PICOTS framework to the upper-tier evidence gaps and translated them into research questions. We then invited the stakeholders to reprioritize the upper tier of the evidence gaps stated as research questions using the same Web -based prioritization tool used in the first round.

After the second round of prioritization, we identified the top-ranked research needs as determined by the stakeholders’ prioritization. We present these in this report as the prioritized FRNs for the comparative effectiveness of FGAs and SGAs in the pediatric and young adult populations. The final list of prioritized research needs was not shared with the stakeholders until the public comment period of the draft report.

## Research Question Development and Research Design Considerations

Using guidance from a draft AHRQ methods paper titled “Framework for Considering Study Designs for Future Research Needs,” we considered several factors and identified potential study designs to address each of the highest-ranked research needs. We considered factors such as advantages of the study design to produce a valid result; resource use, size, and duration; potential social, legal, and ethical issues; and availability of data or ability to recruit participants. We received informal input from the stakeholders on the second conference call regarding study designs, but we did not ask stakeholders to formally rank study designs because such an exercise would add considerably to the length and complexity of the process, and some stakeholders might not have the technical expertise to engage in this process. We present the study design considerations as suggestions to potential funders and researchers. These suggestions are based on a composite evaluation of the extant literature reviewed in the CER,1 relevant ongoing studies, stakeholder input during the future research needs process, and our power and sample size analyses.