# Contributors

Rebecca Bitsko, Ph.D.

CDC National Center on Birth Defects and Development Disabilities

Atlanta, GA

Teri Brister, Ph.D.

Programs for Young Families

Brandon, MS

Jana Davidson, M.D., F.R.C.

BC Mental Health & Addictions Research Institute

Vancouver, BC Canada

Debra Dihoff, M.A.

National Alliance on Mental Illness

Raleigh, NC

Tiffany Farchione, M.D.

Food and Drug Administration, Division of Psychiatry Products

Silver Spring, MD

Laurence Greenhill, M.D.

NYS Psychiatric Institute

New York, NY

Fay Kagan, M.D.

Hathaway Children’s Services

Sylmar, CA 91392

Penelope Knapp, M.D.

Department of Psychiatry and Behavioral Sciences

UC Davis M.I.N.D. Institute

Sacramento, CA

Laurel Leslie, M.D., M.P.H.

Tufts Clinical and Translational Science Institute

Boston, MA

Mark Olfson, M.D., M.P.H.

Columbia University Medical Center

New York, NY

Benedetto Vitiello, M.D.

National Institute of Mental Health

Bethesda, MD

Julie Zito, Ph.D.

University of Maryland School of Pharmacy

Baltimore, MD