# Abbreviations

ADHD: attention deficit hyperactivity disorder
AHRQ: Agency for Healthcare Research and Quality
CER: comparative effectiveness review
CGAS: Children’s Global Assessment Scale
CI: confidence interval
DBDs: disruptive behavior disorders
EG: evidence gap
EHC: Effective Health Care
EMR: electronic medical record
EPS: extra-pyramidal symptoms
ES: effect size
FDA: U.S. Food and Drug Administration
FGA: first-generation antipsychotics
FRN: future research needs
HIPAA: Health Insurance Portability and Accountability Act of 1996
HRQL: health-related quality of life
ICTRP: International Clinical Trials Registry Project
KQ: key question
NIH: National Institutes of Health
NMS: neuroleptic malignant syndrome
NNT: number needed to treat
NRCTs: nonrandomized controlled trials
OCD: obsessive-compulsive disorder
OR: odds ratio
PANSS: Positive and Negative Symptoms Scale
PDDs: pervasive developmental disorders
PICOTS: populations, interventions, comparators, outcomes, time frames, and settings
RCTs: randomized controlled trials
RN: research need
RR: relative risk
SGA: second-generation antipsychotics
SOE: strength of evidence