# Discussion

This project used a structured approach to further refine and prioritize specific areas of future research addressing antipsychotic usage in youth that were necessary to sufficiently address key questions in the CER “First-and Second-Generation Antipsychotics for Children and Young Adults.”1 This project clearly identified evidence gaps described in the report, worked with stakeholders to prioritize this list of gaps and transform them into research questions, further prioritized these needs, and considered PICOTs and potential study designs for the highest-priority needs.

We assembled a diverse team of stakeholders who provided knowledge in the broad and complex area of antipsychotic usage in pediatric mental health. The stakeholder group included clinicians, advocates, researchers, education specialists, and funders. Our conference calls before and after the first round of prioritization revealed several key themes that helped inform our development of the evidence gap list. These themes included a desire for improved understanding of long-term safety risks, improved understanding of how antipsychotics may affect real-world outcomes, and the need for evaluation of generalizable study populations that emphasize comorbidity over diagnostic purity. The stakeholders emphasized the importance of longer-term study periods (years versus months) and de-emphasized the utility of more short-term RCTs. Stakeholders made special note of the lack of patient registries with linkages to clinical datasets as well as the lack of long-term cohort studies that could facilitate comparative effectiveness research to assess benefits and harms over the last several years. This process of refinement helped create a list of 16 evidence gaps that were based on those derived from the CER but also reflected the perspectives of the stakeholders. Our initial prioritization exercise included 14 of the 16 evidence gaps and revealed 8 higher-priority evidence gaps. From this, 6 high-priority research needs emerged.

Although significantly lower than the original number of 14 evidence gap sprioritized by the stakeholders, the final list of 6 highest-ranking research needs incorporates a broad spectrum of issues. The needs identified ranged from methodological considerations to needs emphasizing medication safety issues to clinically oriented effectiveness research needs. Through their rankings, the stakeholders clearly emphasized general medication safety and effectiveness issues over disorder-specific medication effectiveness gaps. This emphasis was notable given the general lack of efficacy data in many of the disorders of interest. In our conference calls, some stakeholders indicated concern that antipsychotics are used with increasing frequency among youth for behavioral symptoms such as irritability and aggression that are common across many disorders rather than for symptoms specific to disorders (e.g., positive symptoms of schizophrenia) or for the disorders themselves. In addition, several stakeholders noted on both conference calls that the established efficacy data for antipsychotics is of low to moderate effect size and more disorder-specific efficacy trials of existing medications should, therefore, not be the focus of research investment. In conference calls, the stakeholders acknowledged that effectiveness studies in this area are hampered by a lack of appropriate, validated, and practical measurement tools to allow for surveillance of effectiveness and safety outcomes in more practice-based and or pragmatic research settings. Of note, this gap related to assessment tools was highly ranked in the first round of gap prioritization but was not among the six highest-ranked items in the second round.

Three evidence gaps gleaned from the CER and identified by our stakeholders were deemed by the FRN team as important but not eligible for ranking. These concerns were either too broad in scope, related to very specific design flaws about which there is broad agreement, or related to sources of bias and were not translatable into scientific research questions. These concerns were left as general recommendations for consideration and are listed below.

- The extant literature lacks large-scale effectiveness studies that are generalizable to the broader population seen in clinical practices.
- The extant literature is limited with regard to efficacy studies with adequate blinding of study participants and outcomes assessors, adequate concealing of allocation, and appropriate handling and reporting of missing data.
- The extant literature is limited with regard to independent/investigator-driven research efforts, which increases the potential for overestimated treatment effects associated with industry-funded research.

In our consideration of potential study designs, we proposed the notion of randomized trials for only some research need areas, reflecting the input of stakeholders who noted the clear pragmatic barriers to answering long-term effectiveness and safety questions with this design. Our consideration of sample size was informative to illustrate the wide range of complexity and resources that would be required to undertake some of the potential trial designs. For example, evaluating between drug differences for weight gain in a prospective cohort design may require up to 400 per group when comparing two drugs and becomes notably more resource intensive for the comparison of three or more drugs. In such cases, sample size and cost will need to be weighed carefully against the importance of the research question. Large prospective cohort designs that follow youth with a range of mental health disorders and treatments would be valuable for comparative effectiveness and safety research but are hampered by cost and difficulties with loss to followup.

It is possible that some of these effectiveness and safety questions could be evaluated with complex secondary data analysis techniques. Unfortunately, datasets from trials are often not useful for these purposes because of short length of followup or lack of appropriate measures. When evaluating shorter-term safety concerns, combining data from trials may be more feasible because some safety outcomes tend to be more homogenous across studies (e.g., weight gain). Meta-analysis is a commonly employed tool in comparative effectiveness research but may not be a feasible tool for many questions because of a lack of studies in an area, study length, or the heterogeneity of populations and measurement tools across existing studies. In some situations where original raw data from previously completed studies could be shared among investigators, advanced techniques such as meta-analysis of individual patient data could potentially be used to deal with the heterogeneity problem.

Patient registries with linkages of patient-reported outcomes to clinical datasets (such as claims or EMR data) are a likely lower-cost approach for some questions about effectiveness and safety. However, such data-linked registries are nascent in mental health and may be hampered by confidentiality issues and methodological limitations. Finally, stakeholders pointed out that any attempt to perform comparative effectiveness evaluations involving FGAs in youth outside of randomized trials would be hampered by the low prevalence of use of these agents in the community. Further, stakeholders discussed the notion that even large comparative trials between FGAs and SGAs for youth and or young adults may be hampered by applicability and feasibility because few clinicians would be inclined to use FGAs, except in the case of schizophrenia.

## Limitations and Challenges

Stakeholder participation. The nature of the stakeholder process lends itself to certain important limitations. Although stakeholder input was essential, scheduling challenges led to incomplete participation from some members. To accommodate this challenge, we provided opportunities for stakeholders to provide feedback by email, but we did not speak with stakeholders by telephone individually. To account for the possibility that stakeholders who attended conference calls were unable to express an opinion during a call in which they participated, we provided the opportunity to offer further comment by email.

Key challenges related to gap development and presentation. The process required that we strike a balance between the need to develop a list of digestible evidence gaps with a diverse group of stakeholders and the need to remain faithful to the purpose, findings, and intent of the original CER on antipsychotics in youth. An inherent strength of the process is that neither the findings of the systematic review nor the views of the stakeholder panel fully dominate the final product.

In developing the gaps, we arranged them by key question from the CER.1 Because of this organizational scheme, gaps associated with different key questions may have appeared quite similar and/or overlapping to stakeholders. For example, a stakeholder may have had trouble distinguishing between or prioritizing a gap about lack of long-term effectiveness data for a particular disorder versus a gap about long-term effectiveness data for antipsychotic use in youth in general. Some stakeholders may have been more accustomed to considering evidence gaps and research needs from their particular field of work and might have found it difficult to interpret and prioritize research questions written and organized by other authors. The project team and the stakeholders raised the question of whether gaps might be made more digestible if organized by theme or domain. For example, one proposed schema broke the gaps into methodological, treatment intervention-oriented, and outcome-oriented gaps.

We worked to minimize the risk of arbitrary exclusion of gaps or needs by erring on the side of inclusion when cut points were not clear. Further, we provided the opportunity for discussion after the first round of prioritization on the subject of re-elevating low ranking gaps for inclusion for the second round of prioritization. However, the stakeholder group did not reach consensus on re-elevating any particular low ranking gap after the first prioritization exercise. Of note, the stakeholder process is not intended to delineate a clear rank order of research needs. Further, all of the generated comparative effectiveness evidence gaps have potential public health value and are listed in Table 2 in the results section of this report.