# Conclusions

Overall, the stakeholders demonstrated engagement in our discussions of research challenges in the field and were able to perform the ranking process without difficulty. The six high priority research needs (Table 7) included a broad range of issues cutting across disorders, key clinical outcomes, safety outcomes, and methodological concerns. The prioritization revealed emphasis on safety and effectiveness needs across youth mental conditions rather than within disorder subgroups with the exception of bipolar disorder and schizophrenia. PICOTS development aided our consideration of study design issues and our sample power analyses demonstrated the clear pragmatic barriers that many of the potential designs will present. While large long-term multi-site clinical trials may be the gold standard to assess many of the questions of importance, feasibility has greatly limited the number of such large pragmatic trials in mental health to date. Large prospective cohort studies of youth exposed to antipsychotics may be viable and offer considerable analytic flexibility, but are also costly. Patient registries with linkages to clinical data sets may allow for more efficient evaluation of some questions with advanced analysis methods, but the infrastructure for this needs considerable investment and its development may face considerable hurdles relating to information privacy. Meta-analysis of existing trials data and meta-analysis of individual patient data may prove helpful, but will likely be limited to evaluation of specific shorter term outcomes. Despite its limitations, the structured process used in this project may prove to be an effective way of reaching relative consensus on research priorities in this broad and complex topic area.

Table 7 Six high priority research needs identified by stakeholders

What is the long-term comparative effectiveness between and within classes of antipsychotics as measured in outcomes related to the disorder of interest, its co-morbidities, associated behavioral features, social-occupational outcomes, and outcomes identified as important by patients and their families?
What are the comparative long-term risks of medication exposure between and within antipsychotic classes?
What is the efficacy and effectiveness of first or second generation antipsychotics for adolescents and young adults with schizophrenia in the following outcome domains: core features of the disorder, its commonly associated co-morbidities and behavioral features, social/occupational functioning, patient and parent reported outcomes, those related to high risk behaviors, and suicide related behavior?
Are there subgroups of patients based on baseline demographic/clinical characteristics or physical and/or mental health co-morbidities for which first and second generation antipsychotics differ in efficacy, effectiveness, or frequency of adverse events?
What is the efficacy and effectiveness of first or second generation antipsychotics for individuals with attention deficit hyperactivity disorder and disruptive behavior disorders in the following outcome domains: core ADHD symptoms, its commonly associated co-morbidities and behavioral features, social/occupational functioning, patient and parent-reported outcomes, those related to high risk behaviors, and suicide related behavior?
What is the efficacy and effectiveness of first or second generation antipsychotics for adolescents and young adults with bipolar disorder in the following outcome domains: core features of the disorder, its commonly associated co-morbidities and behavioral features, social/occupational functioning, patient and parent-reported outcomes, those related to high risk behaviors, and suicide related behavior?