# Background

## Objective

The purpose of this future research needs (FRN) report is to develop a list of stakeholders’ research needs related to the comparative effectiveness of first- and second-generation antipsychotics (FGAs and SGAs) in pediatric and young adult populations.

## Context

This FRN report is based on an Agency for Healthcare Research and Quality (AHRQ) comparative effectiveness review (CER) titled “First- and Second-Generation Antipsychotics for Children and Young Adults.”1 We reviewed the CER in draft form. The purpose of the CER was to review and synthesize the evidence regarding the benefits and harms of FGAs and SGAs for the treatment of various psychiatric and behavioral conditions in children and young adults 24 years of age or younger.

FGAs and SGAs are commonly categorized into two classes (Appendix A includes lists of FGAs and SGAs). FGAs, also known as typical antipsychotics, were developed in the 1950s (Appendix A, Table A-1). FGAs are used to treat psychotic symptoms such as auditory and visual hallucinations and delusions through several proposed mechanisms, including through the blockade of dopamine neuro-receptors. FGAs are associated with various adverse effects. These side effects include extra-pyramidal symptoms (EPS). EPS is a group of movement disorders, including acute dystonic reactions (severe spasms of various muscle groups), akathisia (a feeling of motor restlessness), pseudo-parkinsonism (medication-induced motor slowness and rigidity), and tardive dyskinesia (repetitive low amplitude movements, most often of facial muscles, insidious and chronic in nature). The most severe antipsychotic-associated potential side effect is neuroleptic malignant syndrome (NMS), characterized by hyperthermia, rigidity, rhabdomyolysis, renal failure, delirium, cardiovascular instability, and death. SGAs, also known as atypical antipsychotics, emerged in the 1980s. SGAs (Appendix A, Table A-2) are generally thought to have a lower risk of EPS.2,3 The risk of NMS is rare for both medication classes, and researchers are uncertain about whether there is an intra-class risk difference for NMS.4 However, SGAs are associated with a higher risk of a range of metabolic side effects, including weight gain; dyslipidemia; insulin resistance; the development of type 2 diabetes; and, rarely, hyperglycemic coma.2

The review1 was prompted by the observation that the use of antipsychotics, particularly SGAs, for children and adolescents has increased markedly during the past 20 years.5–9 Prescribing antipsychotics to the pediatric population is controversial because of a relative lack of high-quality and longitudinal studies on which to base clinical practice recommendations. For the majority of antipsychotic drugs, approved indications in the United States are restricted to the treatment of childhood schizophrenia and bipolar disorders. See Appendix A for a list of antipsychotics and FDA-approved indications. The U.S. Food and Drug Administration (FDA) approved risperidone in 2006 and aripiprazole in 2009 for the treatment of irritability associated with autism. Off -label prescriptions are given to younger children for a range of indications including behavioral symptoms (e.g., aggression) that are related to diagnosable conditions (e.g., attention deficit hyperactivity disorder [ADHD]). In general, much prescribing of SGAs for children and adolescents does not appear to be guided by evidence of clinical benefit or risk of harms.10

## Scope of Comparative Effectiveness Review

The CER1 focused on the following key questions to address the issues presented above.

Key Question 1. What is the comparative efficacy or effectiveness of first generation antipsychotics (FGAs) and second generation antipsychotics (SGAs) for treating disorder-specific and nonspecific symptoms? Included disorders:

- Pervasive developmental disorders, including autistic disorder, Rett syndrome, childhood disintegrative disorder, Asperger syndrome, and pervasive developmental disorder not otherwise specified;
- Attention deficit hyperactivity disorder (ADHD) and disruptive behavior disorders, including conduct disorder, oppositional defiant disorder, and disruptive behavior disorder not otherwise specified;
- Bipolar disorder, including manic or depressive phases, rapid cycling, and mixed states;
- Schizophrenia and schizophrenia-related psychoses, including schizoaffective disorder and drug-induced psychosis;
- Tourette syndrome;
- Obsessive-compulsive disorder;
- Post-traumatic stress disorder;
- Anorexia nervosa; and
- Behavioral symptoms, including aggression, agitation, anxiety, behavioral dyscontrol, irritability, mood lability, self-injurious behaviors, and sleep disorders.

Key Question 2. Do FGAs and SGAs differ in the following medication-associated adverse events:

- Overall adverse events?
- Specific adverse events?
- Withdrawals and time to withdrawal due to adverse events?
- Persistence and reversibility of adverse events?

Key Question 3. Do FGAs and SGAs differ in the following other short- and long- term outcomes (short-term outcomes are defined as outcomes occurring within 6 months; long-term outcomes are defined as outcomes occurring after 6 months):

- Response rate with corresponding dose, duration of response, remission, relapse, speed of response, and time to discontinuation of medication?
- Growth and maturation?
- Cognitive and emotional development?
- Suicide-related behaviors (including ideation) or death by suicide?
- Medication adherence and persistence?
- School performance and attendance?
- Work-related functional capacity?
- Patient insight into illness?
- Patient-, parent-, or care provider–reported outcomes, including levels of physical activity or inactivity, and diet (e.g., caloric intake, food preferences)?
- Health-related quality of life?
- Legal or justice system interaction (e.g., arrests, detention)?
- Health care system utilization (e.g., protective services, social services)?
- “Outcomes that matter” to children, young adults, and their families?

Key Question 4. Do the efficacy and risks of FGAs and SGAs vary in differing subpopulations including

- Sex?
- Age group (<6 years [preschool], 6–12 years [preadolescent], 13–18 years [adolescent], 19–24 years [young adult])?
- Race?
- Comorbidities, including substance abuse and ADHD?
- Cotreatment versus monotherapy?
- First-episode psychosis versus treatment in context of history of prior episodes (related to schizophrenia)?
- Duration of illness?
- Treatment naïve versus history of previous antipsychotics use?

## Findings of the CER

Results and conclusions from the CER are based on 140 included articles, of which 81 were unique studies.1 The studies included 62 randomized controlled trials (RCTs), 2 nonrandomized controlled trials (NRCTs), and 17 cohort studies (9 prospective and 8 retrospective). The number of participants in the studies ranged from 8 to 335 (median=42). The mean age of study participants ranged from 4.0 to 21.5 years (median=13.6). Few studies included young adults ages 19 to 24 years. None of the included studies examined obsessive-compulsive disorder (OCD), post-traumatic stress disorder, or anorexia nervosa. Overall, 38 studies provided head-to-head evidence on a total of 19 comparisons of different antipsychotics. In addition, 17 studies compared different doses of the same antipsychotic, and 26 studies compared a single antipsychotic with placebo. The CER authors used the EPC GRADE11 method to grade the strength of evidence (SOE) for specific outcomes as insufficient, low, moderate, or high.

For KQ 1, the authors of the CER1 graded evidence directly comparing FGAs with SGAs and antipsychotics within each class as insufficient to draw conclusions, with the exception of studies examining some outcomes for pervasive developmental disorders (PDDs) and schizophrenia, which were graded low.

For most conditions, direct comparative studies meeting study selection criteria were lacking; as a consequence, the majority of the findings in the CER1 involved indirect evidence that compared SGAs with placebo. The CER1 reported that there were not sufficient studies to evaluate or compare either medication class for OCD, post-traumatic stress disorder, or eating disorders. Findings for other disorders are described below.

- PDDs: For PDDs, no statistically significant difference was observed between FGAs and SGAs for behavioral symptoms associated with PDDs based on two RCTS. SGAs were favored over placebo for behavioral symptoms associated with PDDs with low SOE but did not separate from placebo for clinical global impressions. The SOE for these findings was low.
- ADHD and disruptive behavior disorders (DBDs): Among those with ADHD and DBDs, SGAs were superior to placebo for a number of behavior symptoms and clinical global impressions with a moderate SOE rating. There was no difference between SGAs and placebo for aggression or anxiety (low SOE).
- Bipolar disorder: For bipolar disorder, the CER reported that SGAs were favored over placebo for clinical global impressions (moderate SOE) and for the treatment of mania (low SOE). However, SGAs did not differ from placebo for depression symptoms in this group (low SOE).
- Schizophrenia: For schizophrenia, SGAs were favored over placebo for clinical global impressions and for positive and negative symptoms (moderate SOE). SGAs were favored over FGAs for clinical global impressions (low SOE), but no difference was found between the classes for positive and negative symptoms. Several within-class SGA comparisons did not differ on positive and negative symptoms or clinical global impressions (low SOE).
- Tourette syndrome: SGAs were favored over placebo for tics (moderate SOE).

Regarding KQ 2, the CER evaluated the following adverse event outcomes: EPS, insulin resistance, prolactin-related and sexual adverse events, weight gain/body composition side effects, dyslipidemia, and sedation. SGAs were significantly favored over haloperidol for EPS (low SOE). Haloperidol, an FGA, was favored over olanzapine for body composition (low SOE). All other adverse events either lacked sufficient evidence for conclusions or were not significantly different for between -class (SGA vs. FGA) comparisons. This was also true for a number of within-class (SGA vs. SGA) comparisons (low SOE). For all direct comparisons of different FGAs with each other or for indirect comparisons of FGAs with placebo, evidence was insufficient to draw a conclusion for adverse events. For SGAs, adverse event profiles of various SGAs showed that risperidone was favored over olanzapine for dyslipidemia (moderate SOE). Olanzapine was favored over risperidone for prolactin-related events (moderate SOE). Both quetiapine and risperidone were favored over olanzapine for body composition (moderate SOE). For comparisons of SGAs with placebo for nearly all outcomes, the placebo group experienced significantly fewer adverse events than the group receiving SGAs. One exception was a significant effect in favor of aripiprazole over placebo for prolactin-related adverse events (moderate SOE).

For KQ 3, the evidence was rated as insufficient to draw conclusions about either short- or long-term outcomes for health-related quality of life; legal interactions; and other patient-, parent-, or care provider–reported outcomes for all conditions. Short- and long-term outcomes were reported in nine studies examining PDDs and in eight studies examining ADHD and DBDs. Medication adherence was not statistically or clinically different between SGAs and placebo for both conditions (low SOE). Eleven bipolar studies provided data for other outcomes. Medication adherence was statistically significantly better for placebo than for SGAs (RR, 2; 95% CI, 1.0 to 4.0) (low SOE). SGAs and placebo did not significantly differ for suicide-related behaviors (moderate SOE). A total of 22 studies provided data on a variety of short- and long-term outcomes for patients with schizophrenia and related psychosis. The studies found no significant difference in medication adherence between FGAs and SGAs, olanzapine and quetiapine, olanzapine and risperidone, or SGAs and placebo (low SOE). Similarly, SGAs and placebo did not differ in suicide-related behaviors (low SOE). Other outcomes were reported by four studies on Tourette syndrome and two studies on behavioral symptoms; the evidence was insufficient for all of the outcomes and comparisons examined in these studies.

For KQ 4, evidence and conclusions were based on 36 studies that compared outcomes across various patient subpopulations. Sex and age were examined most frequently. Overall, few studies identified differences in the results across subpopulations. Few associations between the patient or clinical variables and outcomes were supported by more than one study. Studies frequently had discordant conclusions in whether there was a significant association between subpopulations and outcomes and the direction of this association.

Because of several common methodological limitations in the studies that were included in the review, the authors concluded that much of the evidence is of low or insufficient strength and limits the ability to draw conclusions. The limitations noted by the CER authors include inadequate blinding of patients and outcome assessors, incomplete outcomes data because of loss to followup and inadequate handling of missing data (this includes cross-overs and the addition of other interventions), and lack of consistency and precision of results across studies because of the use of various scales and surrogate measures for outcomes and small sample sizes. Another limitation of the evidence is that approximately 80 percent of the trials were funded by pharmaceutical manufacturers. Further, few studies reported on key patient-centered health outcomes, and the duration of most studies was short (median of 8 weeks). These characteristics limit the ability to draw conclusions about outcomes such as health-related quality of life; social and occupational functioning; legal interactions; and patient-, parent-, or care provider–reported outcomes and long-term effects of more acute/subacute adverse events such as neuroleptic-induced weight gain on the development of diabetes, dyslipidemia, hypertension, and cardiovascular morbidity. The CER reported that the results of subgroup and regression analyses were often poorly described in the studies (e.g., few studies reported whether an association was significant), limiting the conclusions that could be drawn with respect to subpopulations. Figure 1 shows the relationships between the evidence gaps, PICOTS, and key questions.

Figure 1 Analytic framework depicting relationships between key questions, populations, interventions, outcomes, and components of evidence gaps

Analytic Framework (Figure 1): To the left of center in the figure, a box represents the populations that are the focus of the evidence gaps. These are children and young adults ages 24 years or younger with a diagnosis of any of the included disorders. Included disorders are: pervasive developmental disorder (PDD), attention deficit hyperactivity disorder (ADHD), disruptive behavior disorder (DBD), bipolar disorder (BPD), schizophrenia/schizophrenia-related psychosis (Sz), tic disorders (Tourette syndrome) (TS), obsessive compulsive disorder (OCD), post-traumatic stress disorder (PTSD), eating disorders (anorexia nervosa, bulimia nervosa, eating disorder not otherwise specified) (AN), or nondisorder-specific severe behavioral issues (e.g., aggression) (BS). Below this box, KQ 1 and KQ 4 are specifically noted in parentheses because they refer to targeted populations of either people with a single diagnosis or clinical or demographic subsets of patients with any of the disorders. Dashed lines with arrows pointing toward the box connect this box to two circles located to the right and above the box. The borders of the circles are dashed lines. The text within the circles describes population characteristics that might influence responses to treatment and methods needed to assess prevalence and treatment outcomes. In the first circle, the text reads “Patient selection criteria that matches typical practice.” In the second circle, the text is “Sociodemographic characteristics: sex, race/ethnicity, cotreatment, history of psychosis, duration of illness.” A thick solid line with an arrow leads to the right from the box representing the populations. This line represents the interventions of interest for the evidence gaps. The interventions are listed under the line. These are: first and second generation antipsychotics. Below the line, KQ 2, KQ 3, and KQ 4 are noted in parentheses to indicate the association between these key questions and the interventions and outcomes of interest. Below the list of interventions is a circle with a dashed line border enclosing the phrase “Dosage variations.” A dashed line with an arrow leads from the circle to the phrase “first and second generation antipsychotics.” A curved solid line with an arrow leads down and to the left from the interventions line. The curved line leads to a oval with a solid line border. The adverse effects that could result from some of the interventions are listed inside this oval. The adverse effects are categorized into major and general. The major adverse effects are mortality, cerebrovascular disease- related events, development of diabetes mellitus, diabetic ketoacidosis, neuroleptic malignant syndrome, seizures, extrapyramidal effects, cardiomyopathies, cardiac arrhythmias, agranulocytosis. The general adverse events are weight gain, agitation, constipation, sedation, elevated cholesterol, elevated transaminases, adverse events related to prolactin elevations, galactorrhea, exercise intolerance, precocious puberty. Outside the border and just above the circle, the term “KQ 2” is noted in parentheses to show the association between key question 2 and the potential adverse effects. To the right of the adverse effects circle are two circles each with dashed line borders and dashed lines with arrows leading from them to the adverse effects oval. The text within the first circle reads “Standardized pediatric side-effect scales.” The text in the second circle reads “Direct and indirect comparison of adverse effects.” The thick solid line leading from the population box on the left, ends at two large boxes on the right side of the figure. These boxes contain lists, respectively, of the intermediate and long-term health outcomes of interest. The intermediate outcomes are listed in the first box. These are core illness symptom response rates with corresponding dose and duration of response, acute school performance/attendance, and acute legal/justice system interaction (i.e., arrests, detention). The long-term outcomes are listed in the second box. These are: long-term symptom response rates with corresponding dose, duration of response, remission, relapse, speed of response, time of discontinuation of medication; growth and maturation; cognitive and emotional development; suicide-related behaviors, death by suicide; medication adherence and persistence; school performance/attendance; work-related functional capacity; patient insight into illness; patient/care provider-reporter outcomes (e.g., levels of physical activity/inactivity, diet, food preferences); health-related quality of life (HRQoL); legal/justice system interaction; health care system utilization; direct or indirect impacts from medication use (e.g., development of diabetes mellitus, weight gain, delayed sexual maturation/fertility, bone density, cardiovascular effects, life expectancy, metabolic effects). Located above these boxes are three circles with dashed line borders. Dashed lines with arrows lead from the circles to one or both boxes. The text within the first circle on the left reads “Consensus on clinically meaningful differences.” The dashed lines lead from this circle to both boxes listing the intermediate and long-term outcomes. The text in the middle circle with the dashed border reads “Adequate blinding of study participants, concealment of treatment allocation, handling of missing data.” One dashed line leads from this circle to the long-term outcomes box. The text in the third circle on the right reads “Standardized and comparable measurement for outcomes.” One dashed line leads from this circle to the long-term outcomes box.