# Appendixes

Appendix A Tables of FDA-Approved Indications for First- and Second-Generation Antipsychotics

Appendix B Evidence Gaps Identified in the Draft Comparative Effectiveness Review

Appendix C Flowchart of Future Research Needs (FRN) Process

Appendix D Effective Health Care Program Selection Criteria

Appendix E Searches for Ongoing Research May 23, 2011/June 6, 2011; and List of Relevant Ongoing Studies

Appendix F Online Prioritization Exercises

Appendix G Additional Relevant Characteristics and Study Design Considerations