# Additional Relevant Characteristics and Study Design Considerations

Table G-1 Additional relevant characteristics and study design considerations

| | Producing Valid Results and Bias | Ability to Recruit | Resource Use, Size and Duration | Ethical, Legal, and Social Issues
Clinical Trials | RCT | Best method to control for selection bias and both measured and unmeasured differences between groups at baseline, but this may come at the cost of generalizability. If feasible, this design is likely to produce the most valid results. | Challenge that patients tend to be reluctant to accept randomization. | An RCT has to be large, because the question compares active treatments, and the effect size may be small and easily swamped by other causes of morbidity and mortality in this population. Likely to require substantial resources to recruit large enough sample to evaluate short- and long- term outcomes. | Concerns may occur when treatment is assigned through random allocation. Patients and treating clinicians must perceive equipoise across interventions when invited to participate in a research study. Careful stopping and reporting rules will be important if evidence of significant benefit or harm is found. RCTs are typically performed when there is equipoise on the optimal treatment.
Clinical Trials | NRCT | Ideal design consideration when randomization at the level of the individual is not feasible or ethical. Treatment assignment is not randomized. Thus, consideration of selection bias and unmeasured confounders need to be controlled. The results of assignment of practices will increase the generalizability of the results greatly but will sharply reduce the validity of the results. May be the optimal study design when treatment or exposure cannot ethically or practically be assigned. Baseline characteristics can be measured but may not be balanced between the two groups. If sample size is large, this design may be the best method to assess subgroup effects or incidence of harms. Statistical techniques to adjust for baseline differences may not completely control for potential bias. Crossover may occur, especially in longer duration observation. | Acceptability to potential subjects is better than randomized trials, in which a group is assigned at random. Some disadvantage in that subjects may be less willing to accept any assignment as opposed to patient choice. | Resources needed are generally high but can be less expensive than randomized trials. Study duration will depend on the underlying condition being assessed. For example, duration of acute infectious diseases may require only a brief followup. Because these are prospective studies, duration is longer than retrospective studies. Size will depend on the effect size being sought between intervention and comparator groups. | Concerns may occur when treatment is assigned by investigators. Patients and treating clinicians must perceive equipoise across interventions when invited to participate in a research study. Careful stopping and reporting rules will be important if evidence of significant benefit or harm is found.
Cohort Studies | Prospective Study | A study in which individuals in the group without the outcome(s) of interest (e.g., disease) are classified according to exposure status at baseline (exposed or unexposed) and then are followed over time to determine if the development of the outcome of interest is different in the exposed and unexposed groups. Although high potential for confounding, appropriate repeated measures may increase ability to control for confounding by indication. | More acceptable than designs in which treatment is assigned. Ability to recruit may depend on the respondent burden. | Resources needed are moderate to high; similar to a prospective trial, although less than a study design in which treatment is assigned. Size and duration will depend on the natural history of the condition under study and the effect size or incidence of harm thought to be clinically important. | Because patients and/or providers select the treatment, few ethical issues, although careful stopping and reporting rules will be important if evidence of significant benefit or harm is found.
Cohort Studies | Retrospective Study | A study in which a group of individuals is identified by predetermined common features. The group is usually assembled using available data sources (e.g., administrative data). Individuals are classified according to exposure status (exposed or unexposed) at the time the group existed and are followed up to a prespecified endpoint to determine if the development of the outcome of interest is different in the exposed or unexposed group. Subjects are followed over time. The duration of the study is short because it is retrospective. Significant risk of selection bias, as subjects either choose their treatment or it is assigned by a health care provider. The generalizability of the study result will depend on the population sampled. | Very feasible, main concern is that of selection bias, depending on the source of the secondary data and missing variables. Negotiations with the holders of the secondary data may take significant time. | Less expensive because data used are already collected. The duration of the study is short relative to studies involving primary data collection. However, such studies often take somewhat longer than envisioned. Sample size may be very large given the increasing availability of large administrative claims and EMR databases. | Confidentiality and Health Insurance Portability and Accountability Act issues may arise when diverse databases are linked without specific patient consent.
Cohort Studies | Meta-Analysis of Individual Patient Data | Appropriate for pooling data from existing trials for simultaneous data analysis. In a meta-analysis of individual patient data, individual data from existing studies are brought together using harmonized definitions and reanalyzed according to a prespecified protocol. When individual participant data are available, there is opportunity to standardize outcomes and exposure definitions, and use much more powerful analyses. A major advantage over a meta-analysis of group data is the ability to examine patient-level modifiers of the treatment effect (i.e., patient-level factors such as age, sex, and disease severity indices). | Very feasible, main concern is that of selection bias, depending on the source of the secondary data and missing variables. Negotiations with the holders of the secondary data may take significant time. | Less expensive because data used are already collected. A meta-analysis of individual patient data can take longer to complete than an analysis of a readily available dataset from a single study. Logistical complications include but are not limited to identification of data sources, convincing investigators to participate, standardizing definitions of interventions and outcomes, complying with Health Insurance Portability and Accountability Act and harmonizing definitions of exposures and outcomes across datasets. | Confidentiality and Health Insurance Portability and Accountability Act issues may arise when diverse databases are linked without specific patient consent.
Other | Case Control Study | A study in which participants are identified based on the known outcomes of interest (e.g., medication exposure). Exposure status is then collected based on the participants’ past experiences. Exposure status is compared between the two (or more) groups: those who have the outcome of interest and those who do not have the outcome of interest (controls). This is a retrospective study that collects data on events that have already occurred. | Very feasible, main concern is that of selection bias, depending on the source of the secondary data and missing variables. Negotiations with the holders of the secondary data may take significant time. | Less expensive because data used are already collected. The duration of the study is short relative to studies involving primary data collection. However, such studies often take somewhat longer than envisioned. Sample size may be very large given the increasing availability of large administrative claims and EMR databases. | Confidentiality and Health Insurance Portability and Accountability Act issues may arise when diverse databases are linked without specific patient consent. Otherwise, issues are minimal, given study is observational.

Abbreviations: EMR = electronic medical record; NRCE = nonrandomized controlled trial; RCT = randomized controlled trial