# Online Prioritization Exercises

Figure F-1 Prioritization Exercise #1

Prioritization Exercise #1 (Appendix F, Figure F-1): This figure is an image of a computer screenshot of an online prioritization exercise that lists the 14 evidence gaps ranked by the stakeholders in the first round of prioritization.

Figure F-2 Prioritization Exercise #2

Prioritization Exercise #2 (Appendix F, Figure F-2): This figure is an image of a computer screen shot of an online prioritization exercise that lists the 8 evidence gaps ranked by the stakeholders in the second round of prioritization.