# Searches for Ongoing Research May 23, 2011/June 6, 2011; and List of Relevant Ongoing Studies

## Searches for Ongoing Research May 23, 2011/June 6, 2011

I. NIH Reporter – limited to Active Projects and Award Notice Date greater than February 23, 2010
  antipsychotics, antipsychotic
  Using the OR radio button
  = 264 results
II. HSRProj – Advanced Search screen. Used the same search as the CER draft report appendix; limited to projects with a final year in the range of 2010–2018 (2018 is as high as the search limits go)
  ((asperger) OR (autistic disorder) OR autism OR schizophrenia OR (depression) OR (bipolar disorder) OR (obsessive-compulsive) OR (post-traumatic) OR (anorexia nervosa) OR anorexia) AND (antipsychotics)
  = 8 results
III. WHO ICTRP (International Clinical Trials Registry Platform)
  Advanced Search screen:
  http://apps.who.int/trialsearch/AdvSearch.aspx
  Search in Condition box:
  ((asperger) OR (autistic disorder) OR autism OR schizophrenia OR (depression) OR (bipolar disorder) OR (obsessive-compulsive) OR (post-traumatic) OR (anorexia nervosa) OR anorexia) AND (antipsychotics) AND (child OR adolescent OR pediatric OR infant) = 0 results
  (asperger OR autistic disorder OR autism OR schizophrenia OR depression OR bipolar disorder OR obsessive-compulsive OR post-traumatic OR anorexia nervosa OR anorexia) AND (antipsychotics) AND (child OR adolescent OR pediatric OR infant) = 0 results
  Date of registration between 02/23/2010 and 05/23/2011
  Status = Recruiting (other option is “all”; when I try the second strategy with all, still 0. When I try the search in the title field instead of condition and limit to recruiting studies only, 658 records for 651 trials found.
IV. ClinicalTrials.gov—same strategy as with ICTRP, using “Search Terms” box. In advanced search screen, limited to child+adult (because original search sought infants–24, and child only covers infants–17. This only added one more trial.)
  First Received: From 02/23/2010 to 05/23/2011.
  ((asperger) OR (autistic disorder) OR autism OR schizophrenia OR (depression) OR (bipolar disorder) OR (obsessive-compulsive) OR (post-traumatic) OR (anorexia nervosa) OR anorexia) AND (antipsychotics) AND (child OR adolescent OR pediatric OR infant)
  = 27 results

## List of Ongoing Studies of First- and Second-Generation Antipsychotics in Children and Young Adults as of May 2011

We searched NIH RePORTER, HSRProj, ClinicalTrials.gov, and International Clinical Trials Registry Platform (ICTRP) and obtained 951 records. We dually reviewed information from each record and identified 60 ongoing studies (after removing duplicates) that potentially met the inclusion criteria for the First- and Second-Generation Antipsychotics for Children and Young Adults CER.

Table E-1 List of ongoing studies of first- and second-generation antipsychotics in children and young adults as of May 2011

Reg # | Title | PI | Funder
NCT01098110 | 6-Week Trial of the Efficacy and Safety of Asenapine Compared to Placebo in Subjects With an Acute Exacerbation of Schizophrenia (Study P06124) | Multi-center | Schering-Plough
NCT01136772 | A Comparison of Long-Acting Injectable Medications for Schizophrenia | Scott Stroup, MD, MPH, Columbia University and Joseph P McEvoy, MD, Duke University | National Institute of Mental Health (NIMH)
NCT01149655 | A Long-Term Multicenter, Randomized, Double-Blind, Placebo-Controlled Study to Evaluate the Efficacy, Safety, and Tolerability of Aripiprazole (OPC 14597) as Maintenance Treatment in Adolescent Patients | Eva Kohegyi, MD Otsuka Pharmaceutical Development and Commercialization, Inc. | Otsuka Pharmaceutical Development & Commercialization, Inc.
JPRN-JapicCTI-101147 | A Long-Term, Extended Treatment Study of Aripiprazole in Pediatric Patients with Schizophrenia | Multi-Center (Japan) | Otsuka Pharmaceutical Co., Ltd.
7R34MH080791-04 | A Novel Mulitmodal Intervention for Children with ADHD and Impaired Mood | James Waxmonsky, Florida International University | National Institute of Mental Health (NIMH)
JPRN-MIN000005355 | A randomized open label study of the effects of aripiprazole in overweight and obstructive sleep apnea subjects with schizophrenia or schizoaffective disorder switched from other antipsychotic drugs. | Junichi Murakami, Biwako Hospital Department of Psychiatry | Biwako Hospital
NCT01212575 | A Retrospective NIS to Evaluate the Use of Seroquel XR and IR in the Clinical Practice of Outpatients With Schizophrenia | Charlotte Emborg, Skovager 2, Risskov, Denmark | AstraZeneca
JPRN-JapicCTI-101146 | A Short Treatment Study of Aripiprazole in Pediatric Patients with Schizophrenia | Multi-Center | Otsuka Pharmaceutical Co., Ltd.
NCT01299389 | A Study of Paliperidone Palmitate in Patients With Schizophrenia | None named | Janssen Pharmaceutical K.K.
NCT01206517 | A Study to Evaluate the Safety and Tolerability of Sublingual Asenapine in a Pediatric Population With Schizophrenia or Bipolar I Disorder (Study P06522) | None named | Schering-Plough
NCT01338298 | Adjunctive Aripiprazole | Deanna L. Kelly Pharm.D., BCPP, Maryland Psychiatric Research Center | University of Maryland
NCT01197404 | Affect Management for Early Adolescents | Christopher D. Houck, Rhode Island Hospital | Rhode Island Hospital
5R01MH075921-05 | Antimanic Use During Pregnancy | Katherine Wisner, University Of Pittsburgh | National Institute of Mental Health (NIMH)
NCT01082848 | ARIpiprazole in Anorexia NErvosa | Jaime Moyá, Hospital Clinic of Barcelona | Hospital Clinic of Barcelona
5R01MH078576-05 | Behavioral Intervention to Reduce Novel Antipsychotic Medication Health Risks | Jeffrey Kelly, Medical College of Wisconsin | National Institute of Mental Health (NIMH)
NCT01333072 | Biomarkers in Autism of Aripiprazole and Risperidone Treatment (BAART) | C. Lindsay DeVane, PharmD, Medical University of South Carolina | Medical University of South Carolina
NCT01164059 | Clinical Effectiveness of Newer Antipsychotics in Comparison With Conventional Antipsychotics in Schizophrenia | Dr. Jürgen Timm | University of Bremen
5R01MH082839-03 | Collaboration to Advance Negative Symptom Assessment in Schizophrenia | Jack Blanchard, University of Maryland | National Institute of Mental Health (NIMH)
(From HSR Proj) | Comparative Safety and Effectiveness of Antipsychotics | Stephen Crystal, Institute for Health, Health Care Policy and Aging Research, Rutgers, The State University of New Jersey | Agency for Healthcare Research and Quality
1R01HS018550-01A1 | Comparative Safety of Atypical Antipsychotics in High-Risk U.S. Children with ADHD | David Rubin, Children’s Hospital of Philadelphia | Agency for Healthcare Research and Quality
NCT01213836 | Compare the Effect on Cognitive Functioning of Two Formulations of Seroquel, Seroquel XR and IR in Patients With Stable Schizophrenia | Eva Dencker Vansvik | AstraZeneca
(From HSR Proj) | Comparison of Long-Acting Injectable Medications for Schizophrenia-- ACLAIMS | TS Stroup, NY Psychiatric Institute | National Institute of Mental Health (NIMH)
5K23MH085005-03 | Counteracting Risperidone-Induced Hyperprolactinemia in Youths | Chadi Calarge, University of Iowa | National Institute of Mental Health (NIMH)
(From HSR Proj) | DNA Diagnostics for Minimizing Metabolic Side-Effects of Antipsychotics | Gualberto Ruano, Genomas Inc. | National Institute of Mental Health (NIMH)
5R01HS018577-02 | Drug Cost Containment Changes and Quality of Care for Mentally Ill Dual Enrollees | Steven Soumerai, Harvard Pilgrim Health Care | Agency for Healthcare Research and Quality
NCT01160679 | Effectiveness of Atypical Antipsychotics on Anhedonic Features in Patients With Schizophrenia | Sang-Woo Han, M.D., Ph.D., Department of Psychiatry | Astra-Zeneca
NCT01222793 | Effects of Antipsychotics on Eating and Food Craving in People With Schizophrenia | Kimberly Warren, Ph.D., University of Maryland, Baltimore | National Institute on Drug Abuse (NIDA)
NCT01244815 | Efficacy and Safety of Asenapine Treatment for Pediatric Bipolar Disorder (P06107) | None named | Schering-Plough
NCT01157559 | Efficacy and Safety With Ziprasidone in First-Episode Psychosis | Young Chul Chung, Professor of Psychiatry, Chonbuk National University Hospital, Jeonju, Korea | Chonbuk National University Hospital
NCT01291511 | Efficacy in Prevention of Relapse of Schizophrenia in Subjects Taking Either Placebo or Iloperidone. | None named | Novartis Pharmaceuticals
NCT01256177 | Evaluate the Efficacy and Safety of Quetiapine Fumarate (SEROQUEL) Extended Release as Monotherapy in the Treatment of Patients With Bipolar Depression | None named | AstraZeneca
NCT01184443 | Evaluation of the Efficacy and Safety of Olanzapine for Anorexia Nervosa in Children and Adolescents | Wendy J Spettigue, MD, FRCPC, Children’s Hospital of Eastern Ontario | Children’s Hospital of Eastern Ontario
NCT01349907 | Extension Study of Asenapine for Pediatric Bipolar Disorder (P05898 AM1) | None named | Schering-Plough
NCT01190254 | Fixed Dose Efficacy and Safety Study of Asenapine for the Treatment of Schizophrenia in Adolescents (Study P05896) | None named | Schering-Plough
NCT01190267 | Flexible Dose, Long-Term Safety Study of Asenapine for the Treatment of Schizophrenia in Adolescents (Study P05897) | None named | Schering-Plough
1R03HS019024-01A1 | Identifying Treatment-Resistant Depression in Automated Databases | Darren Toh, Harvard Pilgrim Health Care Inc. | Agency for Healthcare Research and Quality
5R01MH080325-03 | Improving Metabolic Parameters of Antipsychotics Child Treatment | Linmarie Sikich, University North Carolina–Chapel Hill | NIMH
NCT01155544 | Improving Outcomes in Psychosis Associated With Substance Use Using Aripiprazole | Serge Sevy, M.D., M.B.A., Feinstein Institute for Medical Research | NIMH
1R15MH094955-01 | Long-Term Effects of Early-Life Antipsychotic Drug Treatment | Mark E. Bardgett, Northern | National Institute of Mental Health (NIMH)
NCT01142596 | Long-Term Extension Trial of Asenapine in Subjects With Schizophrenia (Study P06125) | None named | Schering-Plough
3R21MH080968-02S1 | Long-Term Safety and Genetic Risk Factors of Risperidone Treatment in Youth | Chadi Calarge, University of Iowa | National Institute of Mental Health (NIMH)
5R01MH045404-19 | Maximizing Treatment Outcome in OCD | Edna Foa, University of Pennsylvania | National Institute of Mental Health (NIMH)
NCT01184235 | Multidimensional Measurement of Psychopharmacological Treatment Response | Bill J Duke, M.A., Ph.D., Child Psychopharmacology Institute | Child Psychopharmacology Institute
5K23MH079498-02 | Neuroprotective/Neurodevelopmental Effects-Antipsychotics in Adolescent Psychoses | Karin Borgmann-Winter, Children’s Hospital of Philadelphia | National Institute of Mental Health (NIMH)
NCT01170117 | Olanzapine Versus Placebo for Outpatients With Anorexia Nervosa | Evelyn Attia, MD, Columbia University Medical Center | National Institute of Mental Health (NIMH)
NCT01227668 | OPT - Phase IV Long Term Maintenance Study of Aripiprazole for the Treatment of Irritability Associated With Autistic Disorder | None named | Bristol-Myers Squibb
NCT01154829 | Pan European Collaboration on Antipsychotic Naive Schizophrenia (PECANS) | Birte Y Glenthoj, professor, University of Copenhagen, Psychiatric Center Glostrup | University of Copenhagen
NCT01075295 | Prevention of Weight Gain in Early Psychoses | Rohan Ganguli, MD, Centre for Addiction and Mental Health | Centre for Addiction and Mental Health
NCT01282281 | Prospective Metabolic Monitoring of Youth and Adults With Bipolar Disorder | Ayal Schaffer, MD and Benjamin Goldstein, MD, Sunnybrook Health Sciences Centre | Sunnybrook Health Sciences Centre
NCT01171937 | Risperidone Treatment in Children With Autism Spectrum Disorder and High Levels of Repetitive Behavior | James T. McCracken, M.D., UCLA | University of California, Los Angeles; National Institutes of Health
NCT01117220 | Safety and Efficacy of Ziprasidone In Children and Adolescents With Bipolar I Disorder (Manic Or Mixed) (Protocol A1281196) | None named | Pfizer
NCT01122927 | Safety and Tolerability of Aripiprazole in Adolescents With Schizophrenia or Children and Adolescents With Bipolar I Disorder, Manic or Mixed Episode With or Without Psychotic Features. | None named | Otsuka Pharmaceutical Development & Commercialization, Inc.
NCT01124877 | Safety and Tolerability of Flexible Doses of Oral Ziprasidone In Children and Adolescents With Bipolar I Disorder (Manic or Mixed) | None named | Pfizer
NCT01269710 | Second-Generation Antipsychotic Treatment Indication Effectiveness and Tolerability in Youth (Satiety) Study | Linmarie Sikich, MD, UNC- Chapel Hill | University of North Carolina, Chapel Hill; Foundation of Hope, North Carolina
5R01MH080050-04 | Stepped Pharmacotherapy for Aggressive Youth with ADHD | Joseph Blader, State University New York Stonybrook | National Institute of Mental Health (NIMH)
5R01MH077750-03 | Stimulant and Risperidone for Youth with Severe Physical Aggression | Robert Findling, Case Western Reserve University | National Institute of Mental Health (NIMH)
2U01MH062565-06A2 | Sustaining Remission of Psychotic Depression | Ellen White, University of Pittsburg | National Institute of Mental Health (NIMH)
NCT01119014 | Tolerance and Effect of Antipsychotics in Children and Adolescents With Psychosis | Katrine Pagsberg, Bispebjerg Centre for Child and Adolescent Psychiatry, University of Copenhagen | University of Copenhagen
5R01MH081235-04 | Ziprasidone Augmentation of SSRIs for Treatment-Resistant Depression (TRD) | Richard C. Shelton, Vanderbilt University | National Institute of Mental Health (NIMH)
NCT01172652 | Ziprasidone in Bipolar Disorder With Comorbid Lifetime Panic or Generalized Anxiety Disorder(GAD) | Trisha Suppes, MD, PhD, VA Palo Alto Health Care System & Stanford School of Medicine | VA Palo Alto Health Care System