# Effective Health Care Program Selection Criteria

Appropriateness:

- Represents a health care drug, intervention, device, technology or health care system/setting available (or soon to be available) in the United States.
- Relevant to 1013 enrollees (Medicare, Medicaid, S-CHIP, other federal health care programs).
- Represents one of the priority conditions designated by the U.S. Department of Health and Human Services (HHS).

Importance:

- Represents a significant disease burden, large proportion or priority population.
- Is of high public interest; affects health care decision-making, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular.
- Was nominated/strongly supported by one or more stakeholder groups.
- Represents important uncertainty for decisionmakers.
- Incorporates issues around both clinical benefits and potential clinical harms.
- Represents important variation in clinical care, or controversy in what constitutes appropriate clinical care.
- Represent high costs to consumers, patients, health care systems or payers; due to common use, high unit costs, or high associated costs.

Desirability of New Research/Duplication:

- Would not be redundant (i.e., the proposed topic is not already covered by available or soon-to-be available high quality systematic review by AHRQ or others).

Feasibility:

- Effectively uses existing research and knowledge by considering adequacy of research for conducting a systematic review, and newly available evidence

Potential Impact:

- Potential for significant health impact, significant economic impact, potential change, potential risk from inaction, addressing inequities and vulnerable populations, and/or addressing a topic with clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups.