# Flowchart of Future Research Needs (FRN) Process

Figure C-1 Flowchart of Future Research Needs (FRN) process

FRN Process flowchart (Appendix C, Figure C-1): This figure is a flowchart illustrating the future research needs process. At the top, are two rectangular boxes side by side connected by a dashed line. The text in the box on the left reads “Project team gleans information about evidence gaps from comparative effectiveness review.” The text in the box on the right reads “Project team identifies and invites potential stakeholders.” Seven rectangular boxes, connected to each other by solid lines, appear below these first boxes, and the first one is connected to the upper left box by a solid line. The text in each of the lower boxes reads “Project team scans online databases for related ongoing studies;” “Project team reviews the preliminary list of evidence gaps and the list of ongoing studies with stakeholders and revises them if necessary;” “Stakeholders prioritize evidence gaps;” “Project team receives agreement on upper-tier evidence gaps and PICOTS elements;” “Project team develops research questions based on PICOTS for upper-tier evidence gaps;” “Stakeholders reprioritize upper-tier evidence gaps and related research questions;” “Project team compiles prioritization results and presents highest priority research needs and considerations for potential study designs in report.”