# Evidence Gaps Identified in the Draft Comparative Effectiveness Review

“First- and Second-Generation Antipsychotics for Children and Young Adults”

Reviewed on August 8, 2011

Note: All of the evidence gaps listed below refer to the population of children, adolescents, and young adults (24 years of age or younger).

## I Evidence gaps for specific disorders

### Pervasive Developmental Disorders including Autistic Disorder, Asperger’s Syndrome, and Pervasive Developmental Disorder not otherwise specified

1 The evidence regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics is low or insufficient for the treatment of pervasive developmental disorders including autistic disorder, Asperger’s syndrome, and pervasive developmental disorder not otherwise specified. Key Question (KQ) 1

### Attention Deficit Hyperactivity Disorder and Disruptive Behavior Disorders

2 For those with attention deficit hyperactivity disorder and disruptive behavior disorders, there is moderate strength of evidence to support 2^nd^ generation antipsychotics when compared with placebo for improving behavior symptoms and clinical global impressions. However, the evidence regarding the efficacy and effectiveness of 1st or 2^nd^ generation antipsychotics is low or insufficient for other clinically meaningful outcomes of interest. These other outcomes include: aggression, anxiety, social/occupational functioning, health related quality of life (HRQL), legal interactions, medication adherence, patient and parent-reported outcomes, and suicide related behavior. KQ1

### Bipolar Disorder

3 For those with bipolar disorder, there was moderate strength of evidence to support 2^nd^ generation antipsychotics over placebo for clinical global impressions. However, the evidence regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics is low or insufficient for other outcomes such as: aggression, depression, manic symptoms, social/occupational functioning, health related quality of life (HRQL), legal interactions, medication adherence, patient and parent-reported outcomes, and suicide related behavior. KQ1

### Schizophrenia

4 For those with schizophrenia, there was moderate strength of evidence to support 2^nd^ generation antipsychotics over placebo for several outcomes including Children’s Global Assessment Scale (CGAS), clinical global impressions, and the Positive and Negative Symptoms Scale (PANSS). However, the evidence regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics is low or insufficient for other clinically meaningful outcomes such as: aggression, depressions, manic symptoms, social/occupational functioning, HRQL, legal interactions, medication adherence, patient and parent-reported outcomes, and suicide related behavior. KQ1

### Tourette syndrome

5 For those with Tourette syndrome, there was moderate strength of evidence favoring 2^nd^ generation antipsychotics over placebo for tic symptom improvement. However, the evidence regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics is otherwise low or insufficient for other clinically meaningful outcomes. These other outcomes include: clinical global impressions, obsessive-compulsive symptoms, social/occupational functioning, HRQL, medication adherence, patient and parent reported outcomes, and suicide related behavior. KQ1

### Obsessive Compulsive Disorder, Eating Disorders, and Post Traumatic Stress Disorder

6 There is a paucity of data regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics for the treatment of Obsessive Compulsive Disorder, Eating Disorders, and Post Traumatic Stress Disorder. KQ1

## II Evidence gaps for all included disorders

7 The extant literature lacks sufficient evidence regarding comparisons between and within classes of 1^st^ and 2^nd^ generation antipsychotics for any of the included disorders, behaviors, or outcomes of concern for children and adolescents. KQ1, 2
8 For children and adolescents, the extant literature lacks studies examining the long-term (>6 months follow up) efficacy and effectiveness of 1^st^ and 2^nd^ generation antipsychotics in all disorders and behaviors of interest. The median study duration of 8 weeks may be insufficient for evaluation of long term outcomes including outcomes important to parents and patients such as school performance, emotional development, or legal system interactions. KQ1, KQ2
9 In children and adolescents, the extant literature lacks studies examining the long-term (> 6 months follow up) safety of 1^st^ and 2^nd^ generation antipsychotics in all disorders and behaviors of interest. The median study duration of 8 weeks may be insufficient for evaluating long term adverse outcomes such as obesity, diabetes, or cardiovascular events. KQ2, KQ3

## III Evidence gaps for adverse events and subpopulations

10 In children and adolescents, while there is moderate strength of evidence to favor placebo over several 2^nd^ generation antipsychotics with respect to several adverse event outcomes of interest (e.g. sedation, extra-pyramidal symptoms (EPS), weight gain, dyslipidemia) and there is moderate strength of evidence favoring some 2^nd^ generation antipsychotics over others (e.g. risperidone compared with olanzapine) in regards to weight gain, overall there is insufficient evidence to allow for comparisons between and within classes of 1^st^ and 2^nd^ generation antipsychotics for any adverse event outcome. These outcomes include sedation, EPS, weight gain/body composition, insulin resistance, sexual adverse events, and dyslipidemia. KQ3
11 The extant literature lacks evidence to determine if there are differences in efficacy, effectiveness, or adverse events for any population sub-group. Sub-groups include sex, age, race, co-morbidities, co-treatment, history of psychosis, or duration of illness. KQ4

## IV Evidence gaps for methodological issues

12 The extant literature lacks the use of standardized pediatric side-effect scales (e.g., the Safety Monitoring Uniform Report Form). KQ2
13 The extant literature lacks consistent and comparable outcomes and outcome measurements across the studied disorders and behaviors of concern. KQ3, Methods
14 The extant literature demonstrates a lack of consensus on minimal clinically important differences within many outcomes of interest across disorders. KQ3, Methods
15 The extant literature lacks large-scale effectiveness studies that are generalizable to the broader population seen in clinical practices. Methods/All KQs

## V Overarching methods related evidence gaps

Note: We invite stakeholder input on these gaps, but these will not be part of the list of evidence gaps that will be prioritized. These methodological shortcomings of existing research will be considered when we develop proposed research designs for the highest ranked research needs.

16 The extant literature lacks efficacy studies with adequate blinding of study participants and outcome assessors, the adequate concealing of allocation and the appropriate handling and reporting of missing data. Methods/All KQs
17 The extant literature lacks independent/investigator driven research efforts which increases the potential for overestimated treatment effects associated with industry-funded research. Methods/All KQs