# Tables of FDA-Approved Indications for First- and Second-Generation Antipsychotics

Table A-1 Food and Drug Administration-approved first-generation antipsychotics

Generic Name | Indications | Age Group for Which Approved
Chlorpromazine | Schizophrenia | Adults and children (1–12 years)
Chlorpromazine | Bipolar disorder (mania) | Adults and children (1–12 years)
Chlorpromazine | Hyperactivity | Adults and children (1–12 years)
Chlorpromazine | Severe behavioral problems | Adults and children (1–12 years)
Droperidol | Agitation | Adults and children
Fluphenazine | Psychotic disorders | Adults
Haloperidol | Schizophrenia | Adults
Haloperidol | Tourette syndrome | Adults
Haloperidol | Hyperactivity | Adults
Haloperidol | Severe childhood behavioral problems | Adults
Loxapine | Schizophrenia | Adults and children ≥12 years
Perphenazine | Schizophrenia | Adults and children ≥12 years
Pimozide | Tourette syndrome | Adults and children ≥12 years
Prochlorperazine | Schizophrenia | Adults and children >2 years and >20 pounds
Prochlorperazine | Generalized nonpsychotic anxiety | Adults
Thiothixene | Schizophrenia | Adults and children ≥12 years
Thioridazine | Schizophrenia | Adults and children
Trifluoperazine | Schizophrenia | Adults and children ≥6 years
Trifluoperazine | Generalized nonpsychotic anxiety | Adults

Abbreviations: NA=not applicable

Table A-2 Food and Drug Administration-approved second-generation antipsychotics

Generic Name | Indications | Age Group for Which Approved
Aripiprazole | Schizophrenia | Adults and adolescents (13–17 years)
Aripiprazole | Bipolar disorder (manic/mixed) monotherapy or adjunctive to lithium or valproate | Adults and children (10–17 years)
Aripiprazole | Adjunctive treatment of major depressive disorder | Adults
Aripiprazole | Irritability Associated with autistic disorder | Children (6–17 years)
Aripiprazole | Acute treatment of agitation | Adults
Asenapine | Acute schizophrenia | Adults
Asenapine | Bipolar disorder type 1 (manic/mixed) | Adults
Clozapine | Treatment resistant schizophrenia | Adults
Clozapine | Reduce the risk of suicidal behavior in younger patients with schizophrenia. | Adults
Iloperidone | Acute schizophrenia | Adults
Olanzapine | Schizophrenia Bipolar disorder (manic/mixed) | Adults and adolescents (13–17 years)
Olanzapine | Bipolar disorder | Adults
Olanzapine | Treatment resistant depression | Adults
Olanzapine | Agitation associated with schizophrenia and bipolar I mania | Adults
Paliperidone | Schizophrenia Schizoaffective disorder | Adults
Quetiapine | Schizophrenia | Adults and adolescents (13–17 years)
Quetiapine | Bipolar disorder (acute manic) | Adults, children, and adolescents (10–17 years)
Quetiapine | Bipolar disorder (depression) | Adults
Quetiapine | Bipolar disorder (maintenance) | Adults
Quetiapine | Adjunctive therapy for major depressive disorder | Adults
Risperidone | Schizophrenia | Adults and adolescents (13–17 years)
Risperidone | Bipolar disorder (manic/mixed) | Adults and adolescents (10–17 years)
Risperidone | Irritability associated with autism | Children (5–16 years)
Ziprasidone | Schizophrenia | Adults
Ziprasidone | Bipolar disorder (manic/mixed) | Adults
Ziprasidone | Bipolar disorder (maintenance) | Adults
Ziprasidone | Acute agitation in patients with schizophrenia | Adults

Abbreviations: NA, not applicable