# Acknowledgments

We want to thank the members of our stakeholder panel who gave generously of their time. Their expertise and enthusiasm helped drive this project. We also thank Jennifer Seida, M.P.H., and her colleagues at the University of Alberta EPC, authors of the 2010 draft AHRQ comparative effectiveness review. Thanks also to Mattias Jonsson, Maria Tobin, and Shannon Brode, M.P.H., from the UNC Sheps Center for Health Services Research, for their work in developing our online prioritization tools; Christiane Voisin, M.S.L.S., also from the UNC Sheps Center for Health Services Research, for library support; and our Task Order Officers at AHRQ, Sonia Tyutyulkova, M.D., Ph.D., and Elisabeth Kato, M.D., M.R.P., for support and guidance. We also express our gratitude to RTI staff Loraine Monroe, Publications Specialist, and Sharon Barrell, Editor.