# References

1 Balk EM, Moorthy D, Obadan NO, et al. Diagnosis and Treatment of Obstructive Sleep Apnea in Adults. Comparative Effectiveness Review No. 32. (Prepared by Tufts Evidence-based Practice Center under Contract No. 290-2007-10055-1) AHRQ Publication No 11-EHC052-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
2 Agency for Healthcare Research and Quality. Future Research Needs Projects. 2010. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=521. Accessed September 6, 2011.
3 Balk EM, Chung M, Moorthy D, Chan JA, Patel K, Concannon TW, Ratichek SJ, Chang LKW. Diagnosis of Obstructive Sleep Apnea: Future Research Needs. Future Research Needs Paper No. 11. (Prepared by Tufts Evidence-based Practice Center under Contract No. 290-2007-10055 I) AHRQ Publication No 12-EHC031-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2012. www.effectivehealthcare.gov/reports/final.cfm.
4 Agency for Healthcare Research and Quality. Framework for Considering Study Designs for Future Research Needs (FRN), Draft Comparative Effectiveness Review. Rockville, MD. Agency for Healthcare Research and Quality. September. 2011. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=774.
5 Richards D, Bartlett DJ, Wong K, et al. Increased adherence to CPAP with a group cognitive behavioral treatment intervention: a randomized trial. Sleep. May. 1. 2007;30(5):635-40. [pmid: 17552379].
6 Punjabi NM, Caffo BS, Goodwin JL, et al. Sleep-disordered breathing and mortality: a prospective cohort study. PLoS Medicine. Aug. 2009;6(8):e1000132. [pmid: 19688045].
7 Young T, Finn L, Peppard PE, et al. Sleep disordered breathing and mortality: eighteen-year follow-up of the Wisconsin sleep cohort. Sleep. Aug. 1. 2008;31(8):1071-78. [pmid: 18714778].