# Acknowledgements

## Stakeholder Panel

Elise Berliner, Ph.D.

Agency for Healthcare Research and Quality

Rockville, MD

Carolyn M. D’Ambrosio, M.D., FCCP, DABSM

Director, The Center for Sleep Medicine

Associate Professor of Medicine

Tufts University School of Medicine

Tufts Medical Center

Boston, MA

Gary D. Foster, Ph.D.

Laura Carnell Professor of Medicine and Public Health

Director, Center for obesity Research and Education

Temple University

Philadelphia, PA

Daniel J. Gottlieb, M.D., M.P.H.

Director, Sleep Disorders Center, VA

Boston Healthcare System

Associate Professor of Medicine, Boston

University School of Medicine

Boston, MA

Edward Grandi

Executive Director

American Sleep Apnea Association

Washington, DC

Christian Guilleminault M.D., D.Biol.

Sleep Medicine Division, Stanford University

Stanford, CA

Joseph A. Hanak, M.D.

Chief, Adult Physical Medicine and Rehabilitation

Tufts Medical Center

Boston, MA

Sheri Katz, D.D.S.

President of the American Academy of Dental Sleep Medicine

Darien, IL

Meir Kryger M.D., FRCPC

Physician, Connecticut VA Healthcare System

Professor, Yale University School of Medicine

Hartford, CT

Tracy R. Nasca

Founder and Senior Vice President

Talk About Sleep, Inc.

Chaska, MN

Allan I. Pack, M.B.Ch.B., Ph.D.

The John Miclot Professor of Medicine

Chief, Division of Sleep Medicine

Director, Center for Sleep and Circadian Neurobiology

Perelman School of Medicine at the University of Pennsylvania

Philadelphia, PA

Sanjay R. Patel M.D., M.S.

Division of Sleep Medicine

Brigham and Women’s Hospital

Boston, MA

Jeffrey R. Prinsell, D.M.D., M.D.

Oral & Maxillofacial Surgery

Marietta, GA

Patrick J Strollo, Jr., M.D., FCCP, FAASM

Medical Director, UPMC Sleep Medicine Center

Professor of Medicine and Clinical and Translational Science

Division of Pulmonary, Allergy, and Critical Care Medicine

University of Pittsburgh School of Medicine

Pittsburgh, PA

Victor G. Villagra, M.D., FACP

Chief Medical Officer

National Rural Electric Cooperative Association

Arlington, VA

Thomas Weakley

Director of Operations Owner-Operator

Independent Drivers Association (OOIDA) Foundation, Inc.

Grain Valley, MO

Lichuan Ye, Ph.D., R.N.

Boston College William F. Connell School of Nursing

Boston, MA

Robert W. Zavoski, M.D., M.P.H.

Medical Director

Medical Care Administration

Connecticut Department of Social Services

Hartford, CT

An anonymous Medical Director.

An anonymous Federal agency stakeholder.