# Acronyms

AHI: Apnea-hypopnea index
AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
CPAP: Continuous positive airway pressure (device)
EPC: Evidence-based Practice Center
FRN: Future research needs
MAD: mandibular advancement device
OSA: Obstructive sleep apnea
QALY: Quality-adjusted life-years
RCT: Randomized controlled trial