# Executive Summary^*^ * Please refer to the main report for references.

## Background

The current Future Research Needs (FRN) project was launched shortly after completion of the comparative effectiveness review (CER) on obstructive sleep apnea (OSA). OSA is an important public health issue, due to the considerable mortality and morbidity associated with the condition. The commonly used methods for diagnosing and treating OSA are cumbersome, resource intensive, and often inconvenient for the patient. The Tufts Evidence-based Practice Center (EPC) conducted a CER on diagnostic tools, characteristics of OSA that are predictive of poor outcomes, and treatments for OSA. For the purpose of the FRN process, the original OSA CER was divided into two overarching sections: diagnosis and treatment. This document describes the FRN for treatment of OSA; an accompanying parallel report describes the FRN for diagnosis. The Background, Methods, and description of the challenges are nearly identical between the two reports.

Figure A is an analytic framework to visualize areas of the systematic review in which evidence gaps were identified. Table A summarizes the evidence gaps identified in our review of the treatment of OSA in adults (the CER’s Key Questions 5–7). These gaps in the evidence review limited the ability to make conclusions on the questions asked; thus they formed the initial FRN topics.

Figure A Analytic framework for the treatment of obstructive sleep apnea in adults with evidence gaps

CVD = cardiovascular disease; D = study design; IC = Intervention and comparator; KQ = Key Question; NIDDM = noninsulin dependent diabetes mellitus; O = outcome; P = population; QoL = quality of life

The analytic framework above highlights the evidence gaps in red that were identified as affecting the conclusions for the respective key questions in the CER. The alphanumeric code for the gaps corresponds to the detailed gaps that are listed in Table 1. The first number of the code corresponds to the key question, the following letters represent the PICOD domains, and the last numerical corresponds to the number on the list for that particular key question and domain. Where there is only one gap identified, the last number is dropped. Grayed out portions of the analytic framework are diagnosis-related questions that are covered in the companion report.3

Figure A. Analytic framework for the treatment of obstructive sleep apnea in adults with evidence gaps. Figure A summarizes the evidence gaps identified in our review of the treatment of obstructive sleep apnea in adults. The original analytic framework in the comparative effectiveness review was modified to highlight the relevant key questions (5 to 7) and evidence gaps within the context of PICOD (patient populations, interventions, comparators, outcomes, and study designs of interest). With reference to the coding using in Table A, the arrow linking treatment with health and related outcomes (key question 5) is associated with evidence gaps 5IC1,5IC2, 5IC3, 5IC4, 5D1, 5D2, and 5O. The arrow linking treatment with compliance (key questions 6 and 7) is associated with evidence gaps 6D, 6O1, 6O2, 6O3, 7D, 7IC1, 7IC2, and 7IC3, and 7D. Evidence gaps 5P and 6P are shown near the population of interest, that is, sleep apnea patients.

Table A Evidence gaps affecting conclusions for the Key Questions

Key Question | Category | Evidence Gap
Key Question 5. What is the comparative effect of different treatments for obstructive sleep apnea in adults? Key Question 5a. Does the comparative effect of treatments vary based on presenting patient characteristics, severity of obstructive sleep apnea, or other pretreatment factors? Are any of these characteristics or factors predictive of treatment success? Key Question 5b. Does the comparative effect of treatments vary based on the definitions of obstructive sleep apnea used by study investigators? | Population | 5P: MAD tested primarily in a narrow population.
| Intervention/Comparator | 5IC1: Limited data directly comparing different interventions, except autotitrating CPAP vs. fixed CPAP. 5IC2: Except for CPAP and MAD, limited data comparing treatments to control (no treatment). 5IC3: Surgery inadequately tested in unbiased studies compared with CPAP (or no surgery). 5IC4: No subgroup analyses available for any treatment, addressing either subquestion.
| Outcomes | 5O: Almost no data on clinical outcomes.
| Design | 5D1: Incomplete reporting and inadequate analyses common. 5D2: Few high quality studies with little susceptibility to bias.
Key Question 6. In obstructive sleep apnea patients prescribed nonsurgical treatments, what are the associations of pretreatment patient-level characteristics with treatment compliance? | Population | 6P: Limited data on patients with mild- to moderate-severity OSA.
Key Question 6. In obstructive sleep apnea patients prescribed nonsurgical treatments, what are the associations of pretreatment patient-level characteristics with treatment compliance? | Outcomes | 6O1: No studies evaluated predictors of compliance with MAD or other treatments. 6O2: Inadequate evidence related to nonsleep measure predictors of poor compliance with CPAP. 6O3: Variable definitions of compliance used.
Key Question 6. In obstructive sleep apnea patients prescribed nonsurgical treatments, what are the associations of pretreatment patient-level characteristics with treatment compliance? | Design | 6D: Studies commonly selectively reported analyses, in particular failing to report tested but nonsignificant associations.
Key Question 7. What is the effect of interventions to improve compliance with device use (positive airway pressure, oral appliances, positional therapy) on clinical and intermediate outcomes? | Intervention/Comparator | 7IC1: Large heterogeneity of interventions limited conclusions. 7IC2: Trials rarely used standardized approaches to design treatments. The effects of specific interventions have not been confirmed. 7IC3: Trials addressed only compliance with CPAP.
Key Question 7. What is the effect of interventions to improve compliance with device use (positive airway pressure, oral appliances, positional therapy) on clinical and intermediate outcomes? | Design | 7D: Few high-quality studies with little susceptibility to bias.

CPAP = continuous positive airway pressure device; MAD = mandibular advancement device; OSA = obstructive sleep apnea

## Methods

### Stakeholder Involvement

FRN topics nominated for prioritization were identified based on recommendations from the original CER and through an iterative process utilizing a diverse stakeholder panel. After a formal recruitment process, participating panelists were asked to review, discuss, and nominate for prioritization CER-derived FRN topics, as well as submit additional topics for FRN consideration. The panel consisted of patient advocates, providers, purchasers, payers, policy makers, researchers and product makers, representing the full range of stakeholders who may use research evidence in health care and public health decisionmaking.

### Use of Microsoft^®^ SharePoint

The EPC developed a secure, password-protected Microsoft® SharePoint Web site, primarily to host the online stakeholder discussions of the FRN topics. The SharePoint Web site also functioned as a platform for Tufts EPC staff to post project announcements and reference documents.

Throughout the open discussion period, stakeholders could use SharePoint to submit new FRN topics; a direct email to EPC staff was also an option. The EPC reviewed and refined all stakeholder-submitted topics. EPC staff posted these topics, along with the CER-derived FRN topics, on the SharePoint Web site for stakeholder discussion.

Each FRN topic was posted as a separate “discussion board.” For their discussions, stakeholders were asked to consider four dimensions of need related to the proposed topic: (1) importance; (2) desirability of research/duplication; (3) feasibility, and (4) potential impact. Stakeholder participation was encouraged and monitored throughout the discussion period, and Tufts EPC staff monitored discussion boards daily to ensure appropriateness and relevance of all comments.

### Approach to Prioritization

After the close of the online discussion period, stakeholders were asked to identify up to 10 FRN topics—considering the topic’s importance, desirability, feasibility, and potential impact—that were of highest priority and that met the Effective Health Care Program selection criteria. Nomination was conducted by email and individual phone calls. After nomination, the EPC grouped similar topics into overarching topics and categorized them into four groups: (1) high-priority topics; (2) second-tier priority topics; (3) topics of little interest to stakeholders, and (4) topics not meeting Effective Health Care Program appropriateness criteria.

### Research Question Development and Considerations for Potential Research Design

For each “high-priority” FRN topic, EPC staff considered the range of study designs that would best address the topic. To determine candidate study designs, the feasibility of the study designs, and sample size calculations, we followed the structure laid out in the Future Research Needs document “Framework for Considering Study Designs for Future Research Needs.”4 For each topic, we described our assumptions about the most appropriate PICOD (Population, Intervention, Comparator, Outcomes, study Design) criteria, in particular describing the advantages and disadvantages of various potential research designs. We specifically considered the feasibility of the research questions focusing on potential sample size, time, and recruitment issues.

## Results

Table B lists the final FRN topics.

Table B List of future research needs topics

High Priority Future Research Needs Topics
1. What is the impact of treatment of sleep-disordered breathing on major long-term clinical outcomes, including mortality, cardiovascular disease, and diabetes?; a. What are long-term outcomes of mandibular advancement devices (MAD) treatment?
2. Cost-effectiveness analysis of a management strategy (diagnosis of symptomatic or high-risk patients through treatments of patients diagnosed with OSA), specifically for patients with mild to moderate disease severity; a. Research on CPAP devices that are both economical as well as clinically effective
3. Comparative studies of different sleep apnea treatments based on patient characteristics; a. Analyses of CPAP stratified by disease severity; b. Analyses of non-CPAP treatments stratified by disease severity; c. Comparison of alternative treatments for patients who do not tolerate CPAP
4. Trials to improve compliance with CPAP, MAD, and other treatments, particularly evaluating cognitive therapy approaches
5. What is the association between sleep apnea severity and long-term clinical outcomes?
Second-Tier Future Research Needs Topics
6. What are the barriers to, and predictors of, compliance with different treatments?
7. Direct comparison of compliance rates with different interventions and incorporation of compliance into an overall comparison of effective treatment
8. Trials to evaluate weight-loss programs as an adjunctive treatment for sleep apnea; a. What is the value of bariatric surgery for treatment of sleep apnea?
9. What is the value of including a sleep medicine specialist in the management of the patient with obstructive sleep apnea?
Other Future Research Needs Topics
10. What is consumer willingness to pay for treatment, to identify consumer preferences for strategies to treat sleep apnea?
11. What are the financial barriers to access to treatment?
12. Role of surgery for treatment of OSA; a. Comparison of surgery versus CPAP; b. Role of orthognathic surgery (corrective jaw surgery); c. Comparison of genio-tubercle advancement versus dental devices
13. Evaluation of postoperative CPAP for all patients with OSA or at high risk of OSA undergoing any surgery with sedation
14. Trials comparing CPAP versus pharmaceutical interventions
15. Trials comparing different CPAP masks
16. Trials comparing CPAP versus oropharyngeal exercises
17. Trials comparing different degrees of mandibular advancement
18. Studies of factors influencing therapist decisions concerning CPAP mask choice
19. Research into how to maintain patients in sleep apnea studies (where dropout rates are unacceptably high)

### High-Priority Future Research Needs Topic 1

#### What is the impact of treatment of sleep-disordered breathing on major long-term clinical outcomes, including mortality, cardiovascular disease, and diabetes? a. What are long-term outcomes of mandibular advancement devices (MAD) treatment?

There was insufficient evidence in the CER on the effect of treatment of OSA on clinical outcomes, with only three studies out of 190 comparative studies reporting clinical outcomes. The clinical outcomes of interest are mortality, cardiovascular disease, and diabetes, including surrogate or intermediate markers of the latter two conditions. In assessment of comparative effectiveness, the two overarching comparisons of interest would be autotitrating (and other nonfixed) continuous positive airway pressure (CPAP) devices versus fixed CPAP devices and CPAP devices versus the mandibular advancement device (MAD). To address the overarching FRN topic and its subcomponents, different study designs are proposed.

##### Randomized Controlled Trials

Any future trials of CPAP or MAD should study clinical outcomes. However, these could result in the use of large resources in terms of cost, time, and effort, and the decision to use these resources for conducting trials has to be balanced against the value of information that can be gained from studying clinical outcomes. Based on the event rate in the control arm and the assumed value of relative risk, the number of trial subjects that would be required would vary from less than 100 to around 2,000. Regardless of the relative difference in effects between groups, trials using mortality as an outcome would need a sample size in the thousands, while using surrogate outcomes would need smaller sample sizes. The trial duration and followup for mortality as an outcome would be measured in years, while trials focusing on surrogate outcomes for cardiovascular disease and diabetes can be relatively short term, for example 6 to 12 months. Loss to followup would be a major concern, along with compliance where many patients cross over from one treatment to another.

##### Post Hoc Analyses of Existing Observational Studies

A second-tier option for using existing data to evaluate the effects of different treatment on clinical outcomes would be to perform post hoc regressions or subgroup analyses within observational cohort studies like the Framingham Heart Study, the Wisconsin Sleep Study, or the Nurses Health Study. However, such post hoc analyses may be susceptible to type I error (falsely significant associations) due to multiple testing. These analyses of existing data can be done quickly with modest resources.

##### Observational Studies

Though less informative than randomized trials for the evaluation of comparative effectiveness, observational studies would be less resource intensive in assessing the impact of various treatments. Case-control studies of patients treated for OSA, with or without a clinical outcome (e.g., a myocardial infarction), could also address this question, though they would be subject to all the biases and other problems of any case-control study. Statistical adjustments like propensity score matching could be used to mimic random assignment. Retrospective data could be gathered quickly though prospective cohorts would take relatively more time and effort.

### High-Priority Future Research Needs Topic 2

#### Cost-effectiveness analysis of a management strategy (diagnosis of symptomatic or high-risk patients through treatments of patients diagnosed with OSA), specifically for patients with mild to moderate disease severity a. Research on CPAP devices that are both economical as well as clinically effective

Cost-effectiveness analysis allows the comparison of different interventions on similar benefit, cost, and utility scales. Benefit and cost estimates can have both internal and external validity. The objective of this FRN is to establish better evidence about the costs and benefits of alternative treatment strategies for individual patients with mild to moderate disease severity. This FRN is distinguished from FRN topic 3 (below) on three dimensions: (1) it assesses the expected value (not just benefit) of selected treatments for OSA; (2) it is designed to address these questions for patients with mild to moderate disease, an understudied group; and (3) it proposes to assess expected value from both the societal and patient perspectives. Out-of-pocket expenses for patients with mild to moderate disease were of considerable concern to patients in our stakeholder group. This FRN seeks to address that concern. The companion report presents a similar discussion on the costs and benefits of alternative diagnosis strategies.

##### Systematic Review

Cost-effectiveness analyses were not addressed by the CER. Conducting a systematic review may be the first step to ascertain the level of existing evidence.

##### Cost–Benefit Analysis

A quality-adjusted cost–benefit analysis is recommended, comparing the incremental costs and benefits of different treatments to each other and to a base case of no active treatment. Benefit, utility, and cost estimates may be derived from previous clinical trial data, where available, and otherwise from observational data. These estimates should include clinical, work-related, accident, and quality of life outcomes. Out-of-pocket patient costs should also be included in cost estimates. A societal perspective should be assumed in the main analysis and the patient perspective in a subanalysis. A variety of interventions should be considered, including but not limited to fixed and alternative CPAP, MAD, oropharyngeal and bariatric surgery (both as indicated), phased and combined interventions, and no treatment. Evidence for the effect of most of these treatments on patient-related outcomes is of low strength or insufficient; therefore, sensitivity analyses may be of great value, including ad hoc sensitivity estimates of how effective an intervention must be to be a cost-effective option. Because a cost-effectiveness analysis can draw from previously collected data, the cost, size and duration of such studies can be limited. However, as discussed by the stakeholders, it may be challenging to gather all the relevant data.

### High-Priority Future Research Needs Topic 3

#### Comparative studies of different sleep apnea treatments based on patient characteristics a. Analyses of CPAP stratified by disease severity b. Analyses of non-CPAP treatments stratified by disease severity c. Comparison of alternative treatments for patients who do not tolerate CPAP

For all comparisons between treatments, the CER concluded that the strength of evidence is insufficient to determine which patients might benefit most from treatment or from which treatment. Trials of sleep apnea treatments do not compare their effectiveness in different patient subgroups, or groups stratified by obesity measures, sex, and other patient characteristics. There is a need for subgroup analyses to help clinicians base treatment decisions on baseline characteristics. These analyses can help maximize early effective, tolerable treatment, to better match treatments to specific patient types, and to minimize costly trial and error.

##### Patient-Level Meta-analysis

For several treatments (particularly CPAP and MAD), there are adequate trials to allow meta-analysis, but patient-level meta-analysis would be required to evaluate the differential effects of treatments in different populations. This approach allows unbiased regressions and subgroup analyses, as could be conducted in any individual trial, avoiding ecological fallacy and providing sufficient power to account for interactions. The analyses could be done quickly and with relatively few resources. However, acquiring the data is the usual main obstacle to conducting patient-level meta-analyses.

##### Post Hoc Analyses of Existing Trials

Reanalysis of existing trials could also provide unbiased regressions and subgroup analyses. These could also be conducted quickly and with limited resources. Acquiring the data from single studies can be relatively easy (or a moot point if investigators reanalyze their own data). Such post hoc analyses may be susceptible to both type I error (falsely significant associations) due to multiple testing or type II error (falsely nonsignificant associations) due to lack of statistical power.

##### Randomized Controlled Trials

In general, there is limited or no need for future randomized controlled trials (RCTs) of CPAP or MAD. But future RCTs could investigate whether an interaction term (between the main effect and the predictor variable—the subgroup factor) is statistically significant. For example, the analysis of interest would be whether the relative effectiveness of CPAP and MAD are different in different subpopulations. An a priori RCT would be more definitive than a post hoc analysis, but such a trial would need to be substantially larger than an equivalent trial evaluating only the main effect.

##### Observational Studies

Prospective or retrospective observational studies could evaluate the predictors of effective treatments using multivariable regression to determine which patient characteristics are associated with more successful treatment. Observational studies, particularly retrospective ones, could be conducted with fewer resources than RCTs, but would still need to be large to be powered for the multivariable analyses and would suffer from the inherent biases of observational data.

### High-Priority Future Research Needs Topic 4

#### Trials to improve compliance with CPAP, MAD, and other treatments, particularly evaluating cognitive therapy approaches

The CER concluded that there was a low strength of evidence that some specific adjunct interventions may improve CPAP compliance compared with usual care. None of the included trials reported results on clinical outcomes. No general type of intervention was found to be more promising than others, and these trials generally had small sample sizes with less than 1 year of followup. Particular interventions discussed by the stakeholders included intensive patient education, social support programs engaging spouse or other family support, cognitive behavioral therapy, feedback from daily adherence monitoring, and peer support in a Web-based fashion. The patient advocates on the stakeholder panel described a demand by patients for better training, education, and other means to improve compliance.

##### RCTs of Multicomponent Behavioral Interventions

A well-done RCT will produce the most convincing results, and if patient eligibility criteria and study setting are realistic, it should be fairly applicable to the majority of patients. Several study design considerations need to be addressed before a RCT can be properly designed and carried out, including using established metrics and objective (not self- or provider-reported) data to measure compliance, adopting behavioral change models and theories for designing interventions, and conducting program evaluation during trial period. It would be of greater interest to show long-term (several years) effects on compliance, since in most cases, treatment can be expected to be life long.

### High-Priority Future Research Needs Topic 5

#### What is the association between sleep apnea severity and long-term clinical outcomes?

The CER reported strong evidence demonstrating that baseline AHI >30 events/hr is an independent predictor of all-cause mortality over several years of followup. Evidence for the association of baseline AHI and other long-term clinical outcomes, however, is lacking. To address this research gap, the CER recommended patient-level meta-analyses of existing data from available large cohorts of individuals who had sleep testing. Stakeholders on the FRN panel echoed the need for evidence on the association of baseline AHI and other long-term clinical outcomes—particularly to inform design of studies to assess long-term efficacy of treatment.

##### Patient-Level Meta-analysis

Standard meta-analysis of existing studies is not feasible due to the large degree of clinical heterogeneity in existing studies. Patient-level meta-analysis could overcome these problems by incorporating the differences into a regression analysis and performing a unitary analysis. Existing studies such as the Sleep Heart Health Study and the Wisconsin Sleep Cohort Study can be assessed to determine whether their data include a baseline measure of sleep apnea severity (e.g., AHI), and relevant demographic and clinical variables to allow for patient-level meta-analysis. This approach allows for unbiased regressions and subgroup analyses. Meta-regression could be used to evaluate associations between sleep apnea severity, and other patient characteristics, with long-term clinical outcomes. The analyses could be done quickly and with relatively few resources. However, acquiring the data is the usual main obstacle to conducting patient-level meta-analyses.

##### Post Hoc Analyses of Existing Studies

A second-tier option would be to perform post hoc regressions or subgroup analyses within already published cohort studies. These could also be conducted quickly and with limited resources. Acquiring the data from single studies can be relatively easy. Such post hoc analyses may be susceptible to both type I error (falsely significant associations) due to multiple testing or type II error (falsely nonsignificant associations) due to lack of statistical power.

##### Prospective Natural History Study

If existing studies are inappropriate for post hoc or meta-analyses, prospective natural history studies can be conducted to investigate potential associations between sleep apnea severity and long-term clinical outcomes. Studies would require assessment of baseline sleep apnea severity in a specified patient population and documentation of all relevant demographic and clinical variables over time. Moderate resources may be necessary to recruit and follow a large cohort over a long timeframe.

## Discussion

We implemented a Web-based discussion board in preference over a series of teleconferences because of what we believed would be advantages of the online approach. Particular advantages include greater flexibility for stakeholders; full participation by all stakeholders in all discussions; a full record of all discussions; less time expenditure by stakeholders; and less resource expenditure by EPC staff. However, we encountered low participation rate of stakeholders during most stages of the project. In contrast, conducting an 1.5-hour teleconference for three consumer stakeholders produced nine topic nominations, highlighting the difference in impact between the two communication platforms. Overall, although SharePoint offered the convenience of asynchronous collaboration it seemed to lack appropriate incentives to engage stakeholders.

Several possible solutions exist for these problems; including reducing the number of stakeholders; reverting to conducting a series of teleconferences; using focus groups to allow a full, simultaneous discussion of each topic; combining teleconferences with online discussions; or numerous other similar approaches. Regardless of which type of discussion is held, there may be advantages to limiting the size of the stakeholder panel and to choosing stakeholders who show enthusiasm in joining the panel and participating in discussions.

In summary, the online Web site discussion of numerous topics by a large stakeholder panel was only moderately successful. Various approaches to improve participation and discussion are possible, including increased use of teleconferences, restricting the size and members of the stakeholder panel, and other approaches. More experience with different approaches is needed.