# Background

## Context

Comparative Effectiveness Reviews (CER)—systematic reviews of existing research on the effectiveness, comparative effectiveness, and comparative harms of different health care interventions—are intended to provide relevant evidence to inform real-world health care decisions for patients, providers, and policymakers. In addition to synthesizing the evidence, CERs also identify the gaps in evidence that limit the ability to answer the key research questions. As part of an effort beginning in 2010, the Agency for Healthcare Research and Quality supports its Evidence-based Practice Centers (EPCs) to work with various stakeholders to further develop and prioritize the future research needed by decisionmakers.2 This process is new, and the methods to delineate future research needs (FRN) are not yet fully developed. The current report describes the first experience of the Tufts EPC in a stakeholder-driven process to identify and nominate for prioritization FRN topics (other than a pilot process with a limited involvement of a small number of stakeholders).

The FRN document is intended to inform and support researchers and those who fund research to ultimately enhance the body of comparative effectiveness evidence so that it is useful for decisionmakers. This document describes the process of developing a prioritized list of research needs with considerations of the advantages and disadvantages of various potential research designs to help researchers and funders develop future research proposals or solicitations, respectively. This process begins with identification of evidence gaps from the original CER, followed by the addition of other areas potentially requiring further research, nomination for prioritization of these evidence gaps by stakeholders, and development of potential study designs for the highest priority topics. Although researchers and funders of research are the end-users of the report, the resulting research is meant to improve health care decisions; therefore, the stakeholders for this process include patients, clinicians, research investigators, payers, and policymakers.

The current FRN project was launched shortly after completion of the CER on obstructive sleep apnea (OSA). OSA is an important public health issue, due to the considerable mortality and morbidity associated with the condition. The commonly used methods for diagnosing and treating OSA are cumbersome, resource intensive, and often inconvenient for the patient. The Tufts EPC conducted a CER on diagnostic tools, characteristics of OSA that are predictive of poor outcomes, and treatments for OSA.1 For the purpose of the FRN process, the original OSA CER was divided into two overarching sections: diagnosis and treatment. This document describes the FRN for treatment of OSA; an accompanying parallel report describes the FRN for diagnosis.3 For the most part, the Background, Methods, and description of the challenges are nearly identical between the two reports.

## Evidence Gaps

Figure 1 is an analytic framework to visualize areas of the systematic review in which evidence gaps were identified. Table 1 summarizes the evidence gaps identified in our review of the diagnosis of OSA in adults (the CER’s Key Questions 5–7). These gaps in the evidence review limited the ability to make conclusions on the questions asked; thus they formed the initial FRN topics.

Figure 1 Analytic framework for the treatment of obstructive sleep apnea in adults with evidence gaps

CVD = cardiovascular disease; D = study design; IC = Intervention and comparator; KQ = Key Question; NIDDM = noninsulin dependent diabetes mellitus; O = outcome; P = population; QoL = quality of life

The analytic framework above highlights the evidence gaps in red that were identified as affecting the conclusions for the respective key questions in the CER. The alphanumeric code for the gaps corresponds to the detailed gaps that are listed in Table 1. The first number of the code corresponds to the key question, the following letters represent the PICOD domains, and the last numerical corresponds to the number on the list for that particular key question and domain. Where there is only one gap identified, the last number is dropped. Grayed out portions of the analytic framework are diagnosis-related questions that are covered in the companion report.3

Figure 1. Analytic framework for the treatment of obstructive sleep apnea in adults with evidence gaps. Figure 1 summarizes the evidence gaps identified in our review of the treatment of obstructive sleep apnea in adults. The original analytic framework in the comparative effectiveness review was modified to highlight the relevant key questions (5 to 7) and evidence gaps within the context of PICOD (patient populations, interventions, comparators, outcomes, and study designs of interest). With reference to the coding using in Table 1, the arrow linking treatment with health and related outcomes (key question 5) is associated with evidence gaps 5IC1,5IC2, 5IC3, 5IC4, 5D1, 5D2, and 5O. The arrow linking treatment with compliance (key questions 6 and 7) is associated with evidence gaps 6D, 6O1, 6O2, 6O3, 7D, 7IC1, 7IC2, and 7IC3, and 7D. Evidence gaps 5P and 6P are shown near the population of interest, that is, sleep apnea patients.

Table 1 Evidence gaps affecting conclusions for the Key Questions

Key Question | Category | Evidence Gap
Key Question 5. What is the comparative effect of different treatments for obstructive sleep apnea in adults? Key Question 5a. Does the comparative effect of treatments vary based on presenting patient characteristics, severity of obstructive sleep apnea, or other pretreatment factors? Are any of these characteristics or factors predictive of treatment success? Key Question 5b. Does the comparative effect of treatments vary based on the definitions of obstructive sleep apnea used by study investigators? | Population | 5P: MAD tested primarily in a narrow population.
| Intervention/Comparator | 5IC1: Limited data directly comparing different interventions, except autotitrating CPAP vs. fixed CPAP. 5IC2: Except for CPAP and MAD, limited data comparing treatments to control (no treatment). 5IC3: Surgery inadequately tested in unbiased studies compared with CPAP (or no surgery). 5IC4: No subgroup analyses available for any treatment, addressing either subquestion.
| Outcomes | 5O: Almost no data on clinical outcomes.
| Design | 5D1: Incomplete reporting and inadequate analyses common. 5D2: Few high quality studies with little susceptibility to bias.
Key Question 6. In obstructive sleep apnea patients prescribed nonsurgical treatments, what are the associations of pretreatment patient-level characteristics with treatment compliance? | Population | 6P: Limited data on patients with mild- to moderate-severity OSA.
Key Question 6. In obstructive sleep apnea patients prescribed nonsurgical treatments, what are the associations of pretreatment patient-level characteristics with treatment compliance? | Outcomes | 6O1: No studies evaluated predictors of compliance with MAD or other treatments. 6O2: Inadequate evidence related to nonsleep measure predictors of poor compliance with CPAP. 6O3: Variable definitions of compliance used.
Key Question 6. In obstructive sleep apnea patients prescribed nonsurgical treatments, what are the associations of pretreatment patient-level characteristics with treatment compliance? | Design | 6D: Studies commonly selectively reported analyses, in particular failing to report tested but nonsignificant associations.
Key Question 7. What is the effect of interventions to improve compliance with device use (positive airway pressure, oral appliances, positional therapy) on clinical and intermediate outcomes? | Intervention/Comparator | 7IC1: Large heterogeneity of interventions limited conclusions. 7IC2: Trials rarely used standardized approaches to design treatments. The effects of specific interventions have not been confirmed. 7IC3: Trials addressed only compliance with CPAP.
Key Question 7. What is the effect of interventions to improve compliance with device use (positive airway pressure, oral appliances, positional therapy) on clinical and intermediate outcomes? | Design | 7D: Few high-quality studies with little susceptibility to bias.

CPAP = continuous positive airway pressure device; MAD = mandibular advancement device; OSA = obstructive sleep apnea