# AHRQ’s Effective Health Care Program Selection Criteria for New Research

1. Appropriateness | 1a. Represents a health care drug, intervention, device, technology, or health care system/setting available (or soon to be available) in the United States
1. Appropriateness | 1b. Relevant to 1013 enrollees (Medicare, Medicaid, S-CHIP, other federal health care programs)
1. Appropriateness | 1c. Represents one of the priority conditions designated by the Department of Health and Human Services (DHHS)
2. Importance | 2a. Represents a significant disease burden; large proportion or priority population
2. Importance | 2b. Is of high public interest; affects health care decisionmaking, outcomes, or costs for a large proportion of the US population or for a priority population in particular
2. Importance | 2c. Was nominated/strongly supported by one or more stakeholder groups
2. Importance | 2d. Represents important uncertainty for decisionmakers
2. Importance | 2e. Incorporates issues around both clinical benefits and potential clinical harms
2. Importance | 2f. Represents important variation in clinical care, or controversy in what constitutes appropriate clinical care
2. Importance | 2g. Represents high costs due to common use, to high unit costs, or to high associated costs to consumers, to patients, to health care systems, or to payers
3. Desirability of New Research/Duplication | 3. Would not be redundant (i.e., the proposed new research is not sufficiently researched by AHRQ or others, considering both completed and in-process research)
4. Potential Impact | 4a. Potential for significant health impact:; - To improve health outcomes; - To reduce significant variation in clinical practices known to be related to quality of care; - To reduce unnecessary burden on those with health care problems
4. Potential Impact | 4b. Potential for significant economic impact:; - To reduce unnecessary or excessive costs
4. Potential Impact | 4c. Potential for change:; - The proposed topic exists within a clinical, consumer, or policymaking context that is amenable to evidence-based change; - A product from the EHC program could be an appropriate vehicle
4. Potential Impact | 4d. Potential risk from inaction:; - Unintended harms from lack of prioritization of a nominated topic
4. Potential Impact | 4e. Addresses inequities, vulnerable populations (including issues for patient subgroups)
4. Potential Impact | 4f. Addresses a topic that has clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups
5. Capacity | 5a. Efficiency (i.e., considering the timing of the need for new evidence, it is likely that a result could be produced in a timely manner)
5. Capacity | 5b. Utilizes existing AHRQ resources or builds desired additional research capacity or decisional support for the EHC Program
5. Capacity | 5c. Costs associated with the likely study design are reasonable considering limited program resources