# Results

## Composition of Stakeholder Panel

Through our multipronged approach to compiling the stakeholder panel, we enlisted a total of 27 stakeholders, of whom 21 were on the diagnosis panel. Table 2 summarizes the number and types of stakeholders on the panel.

Table 2 Stakeholders panel for diagnosis of sleep apnea

Category | Subcategory | No. of stakeholders
Patients and the public | Patient advocates or caregivers | 4
Patients and the public | Current patients | 4
Patients and the public | Transportation sector employers | 4
Providers | Hospital administrator | 6
Providers | Clinicians - Primary care | 6
Providers | Clinicians – Pulmonary care | 6
Providers | Clinicians – Dental care | 6
Providers | Clinicians – Psychiatry | 6
Providers | Clinicians – Sleep medicine | 6
Purchasers | Private employers – Insured or Self-insured | 2
Purchasers | Public purchasers - e.g., Veterans Administration, Federal Employees Health Benefits Plan | 2
Payers | Private insurers | 3
Payers | Medicaid (at the State level) | 3
Policymakers | Agency for Healthcare Research and Quality | 4
Policymakers | Federal agencies | 4
Policymakers | Professional organizations, Guideline developers | 4
Principal investigators | Clinical research | 2
Principal investigators | Health services/policy research | 2
TOTAL | | 21

## Stakeholder Participation and Required Methods Modifications

As noted above, this was the first instance of the Tufts Evidence-based Practice Center (EPC) producing a Future Research Needs (FRN) document with a large number of stakeholders. As such, the process was to a large extent a test of the success of the specific protocol we envisaged. Here we describe the substantive changes that we had to make to the protocol methods.

Overall, the use of the Sharepoint Web site was only moderately successful. The majority of stakeholders were slow to sign on to the Web site, were slow to begin reviewing the ongoing discussions, participated only minimally in discussions, and did not offer new FRN topics. Furthermore, a small number of participants were not able to log in to the Sharepoint Web site because of technical difficulties.

Nineteen FRN topics were discussed and prioritized; the EPC added five of these based on the Comparative Effectiveness Review (CER) Future Research section; stakeholders added eight online (or via email to the EPC); the EPC added six after a teleconference with the consumer advocates (see below).

The discussion period started 12 days after we received signed disclosure of interest forms from almost all the stakeholders (with the exception of the patient stakeholder who we were delayed in recruiting). All participants were contacted 5 days before the online discussion board was made available. We informed them of the impending start of the online discussions as confirmed that their email addresses would be available to them during the course of the discussion. The original plan was for the stakeholder discussion to last 2 weeks; in reality, the discussion period was extended to 27 days to allow further stakeholder involvement. Four of 21 stakeholders signed in to the Web site within 2 days. The median time until stakeholders signed in was 7 days. Seven stakeholders did not log in to the online discussion site at all. The last stakeholder signed in on day 23 of the discussion. Across topics, only five stakeholders started discussions; seven stakeholders participated in the online discussions (added any comments). Not including comments or questions the EPC added, for the 19 topics discussed online, the median number of comments by stakeholders was 2, ranging from 0 (for five topics) to 8. After the discussion period ended, 16 of 21 stakeholders participated in topic nomination (which was conducted by email instead of on the Web site, as originally planned; see below).

To improve participation, after 1 week of discussion, we invited all stakeholders (from both panels) to participate in teleconferences where the EPC reviewed the materials that had been sent to them by email and that were available on the Web site, including the goals of the project, the stakeholders’ responsibilities, the main criteria for selecting and discussing FRN topics, and a review of how to use the Sharepoint Web site. Two calls were scheduled, for which 13 of 27 stakeholders joined (from both diagnosis and treatment panels). To increase participation, we also sent numerous email reminders, offered to have stakeholders email us their comments that we would add to the discussion board, and also answered phone queries on technical issues related to the Web site. Furthermore, because several stakeholders could not easily access the Web site (primarily because of overseas travel), we compiled plain-text versions of all the FRN topics and discussions, which we placed directly into the text of emails (not as attachments). This was emailed to all stakeholders.

Near the true end of the discussion period, we noted that the consumer stakeholders (the patient, the patient advocate, and the representative from the transportation industry) had not participated in the discussion. Upon reviewing the discussions to date, we thought that they might have been too scientifically technical for the lay stakeholders. We contacted them directly, had our suspicions confirmed, and organized a separate teleconference for the three of them (with the EPC). This 1.5-hour teleconference produced six new topics. The EPC organized the discussion into FRN topics, summarized the separate discussions, sent the summary to the lay stakeholders, and then uploaded the topics and discussions to the Web site. A summary of the call was also emailed to all stakeholders. No stakeholders added further to these topic discussions.

After the discussion period was closed, the EPC decided that it was not worthwhile to attempt to use the Web site to have stakeholders nominate the topics. Instead this was done by email. The final list of topics and the text of the discussions were emailed to stakeholders. The order of the topics was randomized once, instead of separate randomization for each stakeholder, since the randomization process was too time consuming. (We chose to maintain links between the list of topics and the topic discussions, rather than manually reorder each stakeholder list.) To prevent procrastination and further delay, we asked stakeholders to nominate the topics within 4 days, by Friday, with the expectation that responses would be in by Monday. Eight of 21 stakeholders sent in the topic nominations by Monday. It was likely that some of the delay in response was due to a weather-related phenomenon (Hurricane Irene) so we extended the timeline and sent out a reminder email after 1 week. Six of the remaining 13 stakeholders sent in their nominations after receiving the email. Subsequently, followup phone calls were made to the remaining stakeholders to solicit their nominations. The final list of nominated topics was received the following Monday. Topics were nominated by 16 of 21 stakeholders. Stakeholders were asked to nominate up to five topics; they prioritized between two and five topics each.

## Research Needs

Based on the methods described above, we organized the FRN topics into three categories (see Methods section): High-priority FRN topics; second-tier priority FRN topics; and other FRN topics. Topics that did not meet minimum requirements for inclusion are not presented. The FRN topics are as listed in Table 3.

Table 3 List of future research needs topics

High Priority Future Research Needs Topics
1. Age- and gender-specific criteria for defining the OSA syndrome (and abnormal breathing)
2. Effect of routine (or selected) preoperative screening for sleep apnea
3. Cost-effectiveness analysis of a management strategy (diagnosis of symptomatic or high-risk patients through treatments of patients diagnosed with OSA), specifically for patients with mild to moderate disease severity
4. Value of having a sleep medicine specialist involved in the diagnosis of OSA (in addition to or instead of a nonspecialist)
5. What is the prognostic accuracy of clinical prediction rules (CPRs) to predict clinical outcomes?
Second-Tier Future Research Needs Topics
6. Indications (patient signs, symptoms, or other features) for appropriate home testing
7. Diagnostic approaches to OSA in obese and nonobese patients
Other Future Research Needs Topics
8. Can PSG be skipped in making the diagnosis of sleep apnea?
9. What are the financial barriers to access to diagnosis?
10. Head-to-head comparisons of portable monitors, questionnaires, and prediction rules
11. Association between use of questionnaires and clinical outcomes
12. What are the available, objectively-measured predictors of sleep apnea diagnosis?
13. What is consumer willingness-to-pay for screening, to identify consumer preferences for strategies to diagnose sleep apnea?
14. Value of scoring nasal flow limitation in recognizing mild OSA
15. Value of brain MRI in evaluating OSA patients
16. Randomized trials of phased testing
17. Value of using 4-phase rhinomanometry in recognition of patients with high nasal resistance and OSA
18. Diagnostic approach to OSA in micrognathia and retrognathia

## High-Priority Future Research Needs Topics

### High-Priority Future Research Needs Topic 1 Age- and gender-specific criteria for defining the OSA syndrome (and abnormal breathing)

#### Background

This FRN topic represents two topics that the stakeholders nominated and discussed separately. After nomination of topics by the stakeholder panel, the topics were combined into one overarching topic.

This overarching topic was addressed in general terms in the Introduction of the CER, but it was not a Key Question in the report. A Technology Assessment preceding the CER provided in-depth discussions on the following issues concerning the diagnosis of abnormal breathing or obstructive sleep apnea (OSA).5 Specifically, the Technology Assessment analyzed whether laboratory-based polysomnography (PSG) is a “gold standard” for measuring abnormal breathing when establishing a diagnosis of OSA. It concluded that most experts consider laboratory-based PSG as the reference method to identify people with apnea-hypopnea index (AHI) suggestive of OSA. However, this does not mean that facility-based PSG is an error-free “gold standard” for measuring abnormal breathing, or that facility-based PSG measurements of breathing are generally sufficient for defining the OSA syndrome. Issues include the questionable reliability of PSG measurements, the variability in AHI scoring criteria, and that AHI does not correlate well with the intensity of the symptoms in patients who are believed to have OSA. Thus, the definition of the OSA syndrome requires information beyond the currently used measurements of breathing. This additional information includes signs and symptoms, and differentiation from other conditions that affect sleep. The lack of a “gold standard” for the diagnosis of OSA is reflected in the design of published studies included in the Technology Assessment and in the CER, where many different thresholds of AHI, ranging from 5 to 40 events/hr, have been used as suggestive of OSA in different studies. None of these studies used age- or gender-specific criteria.

Using AHI scores of ≥5, ≥10, and ≥15 events/hr to estimate the prevalence of sleep-disordered breathing in the general population showed that men had a higher prevalence of sleep apnea than women in middle-age groups (30 to 39, 40 to 49, and 50 to 60 years old) and at all AHI cutoffs.6 The prevalence of the condition among Medicare beneficiaries (people age 65 years or older) is believed to be higher than the aforementioned estimates among middle-age people.5

#### Stakeholder Discussion

The stakeholders stated that there is a need for a new definition of the OSA syndrome that identifies individuals with breathing abnormalities during sleep who have or are at risk of developing clinical sequelae because of their exposure to sleep-disordered breathing. This may require the use of other factors, including symptoms, biomarkers of stress induced by OSA, and markers of genetic risk. A better definition of OSA syndrome will more specifically target therapy at those who are at risk and avoid unnecessary intervention in those who are not. The stakeholders discussed that women generally have a lower AHI than men regardless of symptoms (e.g., snoring) for OSA. Thus, many women may not be diagnosed and remain untreated if using the same diagnostic criteria as men. Moreover, elderly (≥65 years old) may be another important subgroup of patients who need different diagnostic criteria for OSA. The stakeholders pointed out that there exist different AHI diagnostic criteria for school-age children. In the opinions of the stakeholders, studies to unveil age- and gender-specific criteria for defining OSA are feasible and would impact beneficially on treatment decisions and patient outcomes. It was further discussed that experts should be convened to establish standard diagnostic criteria and their corresponding epidemiologic implications for the different severity levels of OSA, and that these be used in future research. However, it was noted that this has already been done by the International Classification of Sleep Disorders (ICSD-2), but that the definition remains problematic.

#### Proposed Research Design

The aim of this topic is to identify age- and gender-specific criteria for defining OSA in individuals who are at increased health risk because of abnormal breathing during sleep. The aim is not to discuss the clinical utility of (yet undefined) age- and gender-specific diagnostic criteria.

To set up criteria for classifying people into categories, such as risk groups for abnormal breathing or OSA, the ideal approach has two stages. The first would be to discover the form of the relationship between specific risk-group criteria in the general population and long-term clinical outcomes. Once the form of the relationship is known, the second stage is to define (age- and sex-specific) thresholds for identifying those who are at increased health risk, that is, patients with the OSA syndrome. In principle, this could be done with (very large) epidemiological cohorts of people who are not receiving treatment for OSA. Obviously, it would be very challenging to design, fund and run such an epidemiological study. Further, a study that evaluates the relationships between AHI (or other PSG measures) and (untreated) clinical outcomes would have to be very long-term and would be unethical for symptomatic patients.

A study that merely describes the distribution of the measurements of breathing (e.g., AHI) in the general population, stratified by sex and age groups, would not conclusively address the challenge of defining OSA as a syndrome. First, currently used measurements of breathing during sleep (including AHI) are probably not sufficient for identifying those at increased health risk (i.e., those with the OSA syndrome); additional information such as signs and symptomsis necessary. Secondly, it does not measure any health-related outcomes that would help deduce which AHI measurements are “not normal”; it would be circular to use AHI (or other PSG measurements) both as a predictor of risk and also as an outcome. Third, it is also not sufficient to use symptoms suggestive of OSA as outcomes, because it is known that AHI scores (or other PSG measures) correlate poorly with symptoms. To establish criteria to predict symptoms would de facto exclude asymptomatic OSA; furthermore a PSG is not needed to determine symptoms. Ideally, one would like to evaluate hard clinical outcomes, such as mortality, cardiovascular disease, and similar endpoints.

Based on the considerations above and for simplicity, we suggest a prospective cohort study of people selected from the general population. The aim would be to associate measurements of breathing with a battery of short-term pathophysiological measurements that distinguish people whose breathing patterns have immediate physiological impact, from those whose breathing patterns do not have measurable functional sequelae.

##### Prospective Cohort Study

###### Value of Study Design

Prospective longitudinal cohort studies are the most informative studies to assess predictors of natural history outcomes (e.g., age and sex as criteria for OSA). A well-designed prospective study will be less biased than a retrospective database analysis. Randomized trials of interventions generally do not provide better data to assess predictors of natural history outcomes.

To set up age- and gender-specific diagnostic criteria for abnormal breathing or OSA, we propose a prospective cohort study of people selected from the general population. All subjects would receive facility-based PSG for sleep-disordered breathing. The primary outcome of interest would be the functional outcomes of the effects of OSA on physiology (“pathophysiological measurements”). Possible functional outcomes include cerebral hypoxia or vasoconstriction. Sleep medicine domain experts would have to choose proxy outcomes that are measurable in the short term (e.g., overnight during a PSG), are highly likely to be due to the apnea, and are highly likely to be the proximate cause of long-term clinical outcomes. Multivariable analyses that control for potential confounders, such as comorbidity and body mass index, would be performed to evaluate the relationship between AHI scores (or other PSG measures) and functional outcomes by sex and age groups. Ideally, all age- and gender-specific criteria derived from such studies would be verified in multiple independent cohorts of patients by independent researchers. It should be noted that the definitive definition of OSA will remain unclear because whether the functional outcomes are good proxy markers for clinical outcomes will likely remain unknown.

With long-term followup, the proposed cohort study can also provide natural history data to be used to assess whether patient characteristics (e.g., age, sex, race/ethnicity), in addition to disease severity, play a role in determining long-term clinical outcomes. Any subsequent treatments and additional diagnostic testing could also be recorded as these data would inform the clinical utility of the age- and gender-specific diagnostic criteria.

###### Resource Use, Size, and Duration

Such a study would require the enrollment of several thousand people. The population-based studies that aimed to estimate the prevalence of sleep-disordered breathing included at least 1,000 individuals. Multivariable analyses would need larger sample sizes than univariable analyses to reach the same statistical power. The study would not impose additional diagnostic testing (beyond the initial PSG) or treatments compared to usual care; therefore, the main nonadminstrative resources would be gathering followup outcome data on all patients. Ideally, the study should follow participants longitudinally with multiple time points for outcome assessments. The followup frequencies should be more often within the first year and then annually.

###### Ability To Recruit

It should be relatively easy to recruit patients into a prospective cohort study. The study would be mostly observational in nature, so the only major added burden to patients would be having an initial PSG and then providing followup outcome data.

###### Ethical Issues

Since no diagnostic decisions or treatments are being imposed on patients, there are no ethical issues directly related to such a study.

### High Priority Future Research Needs Topic 2 Effect of routine (or selected) preoperative screening for sleep apnea

#### Background

Key Question 3 of the CER asked: What is the effect of preoperative screening for sleep apnea on surgical outcomes? The CER found insufficient evidence to address this topic. Two poor-quality studies assessed the effect of preoperative screening for sleep apnea on surgical outcomes. One study found no significant differences in outcomes between patients undergoing bariatric surgery who had mandatory PSG or PSG based on clinical parameters. The second study found that general surgery patients willing to undergo preoperative PSG were more likely to have perioperative complications, particularly cardiopulmonary complications, possibly suggesting that patients willing to undergo PSG are more ill than other patients. No trials have addressed the value of routine (or selected) preoperative screening for OSA.

#### Stakeholder Discussion

Most of the discussion centered on the anecdotal nature of the evidence regarding the perioperative risks in patients with undiagnosed OSA. The stakeholders talked about the concern among anesthesiologists and surgeons about the patients who do not present with high-risk characteristics (e.g., a nonobese patient without obvious airway obstruction), as well as those patients who either fail to wean from the ventilator or have respiratory failure after discharge. These patients were felt to belong to the group of patients undergoing thoracic or abdominal procedures. The respiratory complication rate in patients with OSA was not thought to be high, and it was felt that very large study sample sizes would be needed to evaluate any strategy to identify high-risk patients. The effectiveness of perioperative care was discussed as well as strategies for mitigating risks such as involving experienced anesthesiologists rather than a nurse or resident anesthetist. Furthermore, stakeholders discussed whether the question applies to all surgical cases, only elective cases, or high-risk surgeries (e.g., upper airway surgery, procedures that require patients to remain supine for a period of time postoperatively). Outcomes of interest listed by one stakeholder include time to weaning, days in the intensive care unit, length of hospital stay, and complications such as line infections, ventilator-associated pneumonia, and urinary tract infections. It was also noted that studies may be difficult because they could not be blinded and that behaviors across an institution may change just by virtue of how patients are managed in the trial.

#### Proposed Study Designs

To address the overarching FRN topic and its subcomponents, different study designs are reasonable and would address different aspects of this topic.

##### Randomized Controlled Trials

###### Value of Study Design

The CER found no trials of preoperative screening. A randomized comparison of screening for OSA with extended anesthesia care when appropriate versus no screening with routine anesthesia care would provide information for effectiveness of the screening protocol. However, the sample size calculations below highlight the large number of participants who would need to be recruited for such a randomized controlled trial (RCT). Therefore, the design of choice would likely be a multicenter cluster-randomized trial, where whole centers would be randomized to screen patients or not. The advantage of using a cluster-randomized trial is that there is a minimal risk of protocol deviation if active OSA screening is performed as part of a center’s clinical protocols. There would also be little risk of cross-contamination of the culture of screening for OSA to patients who had been randomized to not receive screening. It is also likely that recruitment and randomization will be logistically easier if it is done at the center level, rather than at the patient level within a center.

###### Resource Use, Size, and Duration

The primary analysis of interest in such a study would be the comparative effectiveness of screening on postoperative morbidity and mortality. The most common instruments that could be used as part of the preoperative bedside screening include questionnaires—Berlin, STOP (Snoring, Tiredness during daytime, Observed apnea, and high blood Pressure), the STOP-Bang (STOP with body mass index, age, neck circumference, and sex variables), the American Society of Anesthesiologists (ASA)screening checklist, and CPRs—based on a combination of clinical measurements, questionnaire answers, airway measurements and demographic variables. The duration of the intervention would be the perioperative period, when followup is routinely done as part of normal clinical practice.

Due to its rarer occurrence, a mortality outcome would necessitate a larger sample size than for an outcome like respiratory complications. However, with the advances in postoperative care, the rates of even complications after surgery have declined considerably, such that sample sizes would need to be large even for these outcomes. To estimated minimum samples sizes (power) we used the data from one of the studies in the report that compared mandatory PSG screening with screening based on clinical riskfactors.7 We used standard formulae for a two-sided equivalence test. We used the postoperative intensive care unit admission rate reported in the study as an outcome. We set the range of relative risk reduction between 0.6 and 0.8, as the study reported a relative risk of 0.6. We set the range of event rates in the control arm from 0.01 to 0.1, as the control arm in the study reported an event rate of 0.05. Assuming a power of 90 percent, the required total sample size (1:1 ratio in a two-arm RCT) for each value of relative risk and the control rate is presented in Figure 4. With the very low rates of postoperative complications, the required sample sizes range from 2,000 to 100,000 participants. If we reduce the power to 80 percent, the range of sample sizes is still large, ranging from 1,500 to 70,000 participants as the relative risk and control rate increases. This highlights the tradeoff that one would have to make between having sufficient power to address the effectiveness of preoperative screening and the large amount of resources that it would need to undertake such a trial. If a convincing argument can be made that a continuous outcome could be an adequate proxy outcome for postoperative complications, then it is likely that a smaller sample size would be needed for adequate power for this outcome. However, it is currently unclear than any continuous outcome would be a convincing proxy.

Figure 4 Sample size calculations for an RCT of screening versus no screening for postoperative complications with varying estimates of risk ratio and control rates

Figure 4. Sample size calculations for a RCT of screening versus no screening for postoperative complications with varying estimates of risk ratio and control rates. Figure 4 is a 3-dimentional bar chart to display the sample size calculations for a randomized controlled trial of screening versus no screening for postoperative complications at 3 hypothetical risk ratios (0.6, 0.7, 0.8) and at 3 control rates (0.01, 0.05, 0.1). At a control rate of 0.01, the sample sizes needed for detecting a risk ratio of 0.8 was 93,712, of 0.7 was 39,354, and of 0.6 was 20,844. At a control rate of 0.05, the sample sizes needed for detecting a risk ratio of 0.8 was 18,060, of 0.7 was 7598, and of 0.6 was 4032. At a control rate of 0.1, the sample sizes needed for detecting a risk ratio of 0.8 was 8602, of 0.7 was 3628, and of 0.6 was 1930.

###### Ability To Recruit

The sampling population is large, as there are thousands of patients who undergo inpatient and outpatient surgery. Patients are usually concerned about intraoperative and postoperative complications and would be interested in using management strategies to mitigate them. If centers, rather than patients, were randomized, it may be possible to consider such a trial to be an examination of an interview procedure, which may allow for a waiver of informed consent. Loss to followup should be rare during the period of hospitalization, but may be of concern for posthospitalization followup unless an adequate system were in place to follow patients.

###### Ethical Issues

The primary ethical issue (beyond the standard ethical issues in conducting an RCT) pertains to whether there is equipoise. It is not known whether performing active preoperative screening for OSA would result in improved perisurgical care and would thus lead to decreased postoperative morbidity and mortality. The use of randomized study designs allows us to answer whether active screening results in improved morbidity and mortality. Thus, there is clinical equipoise.

##### Observational Studies

###### Value of Study Design

Observational studies, such as those that exist, are likely to be fundamentally flawed. In normal clinical practice, preoperative patients who undergo testing for OSA will always be greatly different than unscreened patients. It is unlikely that any amount of statistical adjustment, including propensity scores, could overcome the major clinical differences between the groups of patients. One possible exception to this may be an observational comparison of two or more similar hospitals or clinics where routine screening for OSA is done in some, but not others. However, even in this situation it is unlikely that a convincing argument could be made that any differences in outcomes are primarily due to the use of OSA screening, as opposed to a whole host of other differences that are likely to coexist.

###### Resource Use, Size, and Duration

Retrospective data could be gathered quickly and easily by chart review or similar approaches. Prospective cohorts would take somewhat more time and effort, but would still be less resource intensive than a trial. Since the outcomes ascertainment is potentially completed within a short time frame (within a few weeks) after the operation, data could be collected fairly rapidly, whether retrospective or prospective. However, the validity of the data collected using a flawed study design detracts from the benefit gained by decreased resource utilization.

###### Ability To Recruit

Patient recruitment should be straightforward and relatively simple, as there would be little added burden for them by entering a study, beyond a formalized preoperative screening protocol, all of which are reasonable parts of normal patient care.

###### Ethical Issues

The primary ethical issue involved would be related to recruiting patients and expending resources in a study that is unlikely to provide convincing results.

### High-Priority Future Research Needs Topic 3 Cost-effectiveness analysis of a management strategy (diagnosis of symptomatic or high-risk patients through treatments of patients diagnosed with OSA), specifically for patients with mild to moderate disease severity

#### Background

The topic as proposed covers both diagnosis and treatment strategies for a complete cost-effectiveness analysis. Since diagnosis and treatment FRN topics are being dealt with separately, here we focus primarily on the diagnosis strategy component of the cost-effectiveness analysis. A discussion of a cost-effectiveness analysis of treatment strategies can be found in the companion report.3 It would likely be of value for future cost-effectiveness analyses to incorporate both phases of OSA management (diagnosis and treatment). Cost-effectiveness analysis allows the comparison of different interventions on similar benefit, cost and utility scales. If clinical trial data are available on the treatments and populations of interest, benefit and cost estimates have both internal and external validity.

#### Stakeholder Discussion

The objective of this FRN project is to establish better evidence about the costs and benefits of alternative management strategies for individual patients with mild to moderate disease severity. Ultimately, the goal is to develop evidence about care management from efficient testing of high-risk individuals and accurate and low-cost diagnosis of OSA. Issues that should be considered in a cost-effectiveness model include the patient-related outcomes, including measures of functional status such as productivity (both absenteeism and presenteeism—working in spite of illness, with resulting poor work performance), quality of life, and work safety. The feasibility of such an analysis will depend on combining clinical trial results with health insurance data on health care utilization, employer data on absenteeism, and potentially auto insurance data on motor vehicle accidents in a large cohort of patients with OSA. Other issues that should be considered are the patients’ costs for using OSA treatments. An example of such a cost, which would not be included in most analyses, was the costs to a long-haul truck driver who requires extra battery backup since a continuous positive airway pressure (CPAP) device can drain the truck’s battery overnight.

#### Proposed Study Designs

##### Systematic Review

Cost-effectiveness analyses were not addressed by the CER. Conducting a systematic review may be the first step to ascertain the level of existing evidence.

##### Cost–Benefit Analysis

On the basis of the best evidence identified in the CER, a quality-adjusted cost-benefit analysis is recommended, comparing the incremental costs and benefits of different diagnostic strategies to each other. Benefit, utility, and cost estimates may be derived from previous clinical study data, where available, and from observational data where trial data are not available. These estimates should include not only the standard clinical outcomes, but also work-related, accident, and quality of life outcomes. In the absence of cost estimates, charges may be derived from administrative data and adjusted cost-to charge ratios. Out-of-pocket patient costs should also be included.

###### Analytic Approach

Preference should be given to a Markov-chain, discreet events analysis. The proper outcome measure is quality-adjusted life-years (QALYs) gained. Future QALYs and costs should be discounted over the followup period. Adjustment should be made for major outcomes and adverse events, using rate and utility estimates. Probabilistic sensitivity analyses should be conducted on estimated outcome rates, utilities and cost estimates. A societal perspective should be assumed in the main analysis. The patient perspective should be assumed in a subanalysis, given high out-of-pocket costs for diagnostic strategies and substantial concerns about burden on the patient.

###### Diagnostic Strategies

Diagnostic strategies should be tested both with and without the involvement of a sleep medicine specialist, where possible. Phased treatment combinations should also be considered. A short list of treatment strategies to be compared could include:

- A standard diagnosis procedure (diagnosis using a questionnaire in the primary care setting)
- Other diagnostic algorithms and CPRs
- Portable monitors
- Scoring nasal flow limitation
- Four-phase rhinomanometry
- Brain magnetic resonance imaging

###### Resource Use, Size, and Duration

Because a cost-effectiveness analysis can draw from previously collected data, the cost, size, and duration of such studies can be limited. However, as discussed by the stakeholders, it may be challenging to gather all the relevant data.

###### Ethical, Legal, and Social Issues

No new data collection is proposed, and therefore, the direct risk to patients is minimal.

### High-Priority Future Research Needs Topic 4 Value of having a sleep medicine specialist involved in the diagnosis of OSA (in addition to or instead of a nonspecialist)

#### Background

Increasingly patients with OSA are being diagnosed by primary-care providers. This occurs because some sleep centers allow direct referral for sleep studies and then leave it to the primary-care physician to provide followup. Furthermore, home studies have allowed the primary-care physician to bypass the sleep center altogether. National companies have started marketing the use of home studies to primary-care providers. The CER did not address the effect of having different specialists involved in care. To ascertain the level of existing evidence, it may be prudent to conduct an initial systematic review.

Since most of the scientific studies involving diagnosis of OSA are carried out in highly specialized sleep centers with patients under the supervision of a sleep medicine specialist, it is unknown how effective an approach that does not include input from a sleep specialist would be. Of note, a recent survey found that physicians who specialized in certain fields associated with sleep medicine (pulmonary medicine, neurology, and psychiatry) had different practice patterns compared to other physicians with respect to prescriptions, education, and adherence to CPAP therapy.8 With the high prevalence of undiagnosed OSA, full testing of all individuals at high risk for OSA would likely overwhelm the capacity of sleep centers and sleep medicine specialists.

#### Stakeholder Suggestions

The stakeholders discussed that OSA is sufficiently common that it is unrealistic that millions of patients are going to be able to see a small number of specialists. Requiring the involvement of a sleep specialist may also present a barrier to care in many settings and would likely increase costs. The stakeholders who participated in the discussion were skeptical about the added value of including sleep medicine specialists in the initial diagnosis. However, it was noted that many primary care physicians do not feel adequately trained or comfortable with management of these patients. The stakeholders were interested in comparisons between diagnosis (or more broadly management) by primary care physicians alone, primary care physicians in concert with a specialist, and specialists alone.

#### Proposed Study Designs

Three different study designs are proposed to explore the differences in outcomes when patients are initially diagnosed by sleep specialists or by physicians who are not sleep specialists.

##### Systematic Review

The CER did not address the effect of having sleep specialists involved in care. Conducting a systematic review may be the first step to ascertain the level of existing evidence.

##### Analyzing Claims Data

###### Value of Study Design

One approach to ascertaining cost differences between patients that are diagnosed by specialists as opposed to those diagnosed by nonspecialists is to analyze claims data provided by an insurance provider or a health care system. This approach would require a dataset that included a mix of patients diagnosed by both approaches. One possible dataset would be de identified Medicare and/or Medicaid claims data. This approach would be able to provide a large sample of patients from diverse geographic locations, along with accurate data on cost of care, including physician, diagnostic testing, and treatment costs, as well as outcomes such as time to diagnosis.

An important limitation of this approach is that the analysis is not controlled. Thus, there may be factors associated with seeing a sleep specialist for initial diagnoses that are associated with outcomes that are unrelated to the care provided by the sleep specialist. Despite this, analyzing claims data from different geographical areas would provide a solid basis for further prospectively designed trials.

###### Resource Use, Size, and Duration

Analysis of an existing dataset does not require the substantial costs and time spent with patient recruitment and followup.

###### Ethical Issues

Data would be deidentified and retrospectively analyzed. Thus, there would be no ethical issues in analyzing this data.

##### Post Hoc Analysis of Existing Trials

###### Value of Study Design

Given the breadth of diagnostic and treatment studies analyzed in the existing systematic review of OSA, it could be possible to review these studies to analyze any available information on diagnosis by a sleep specialist versus diagnosis by a nonspecialist. Studies may present this information in a variety of different ways. First, a given study may include only patients that were diagnosed by sleep apnea specialists. Presumably, this would be the majority of studies. Second, a study may include all or some patients from diagnosis by a nonspecialist, or from diagnosis by a team that includes both specialists and nonspecialists. Outcomes from these studies may be compared, if information is given on cost-of-care and/or sleep-related outcomes such as AHI and sleepiness measures (e.g., Epworth Sleepiness Scale). Finally, a study may provide subgroup information on patients that were diagnosed by a sleep specialist or nonspecialist, providing a more direct comparison of outcomes. However, it is likely that to adequately address the topic, data additional to what is included in published articles would need to be gathered. This would depend on the willingness of primary investigators to share their unpublished data.

###### Resource use, Size, and Duration

Reviewing studies included in the existing systematic review would not require costs associated with a prospective study, but could involve a substantial amount of time for reanalyzing a large number of papers.

###### Ethical Issues

Since data would be collected from existing studies, there would be no ethical issues involved.

##### Survey of Providers

###### Value of Study Design

A cross-sectional survey of providers who diagnose patients would provide an in-depth view of issues associated with using a sleep specialist in the diagnosis of OSA. This survey could provide information on the variety and magnitude of issues faced by nonspecialists who may not have the in-depth knowledge of sleep specialists. In addition, this survey could capture specific information related to cost-of-care. This could include information such as number of patients seen per hour as well as factors associated with differential cost-of-care like geographical location and specific field of specialty (e.g., pulmonary medicine, neurology, and psychiatry). The questions asked in the survey would need to be phrased in a neutral fashion to avoid biasing the survey respondents’ answer to favor sleep specialists or nonspecialists with respect to any outcome measure or practice pattern.

###### Resource Use, Size, and Duration

The size of the survey would likely be limited by participation rates. Providers could be contacted who are part of a sleep medicine association to capture specialists as well as primary care providers with an interest in sleep apnea issues. To include primary care providers who are not specifically interested in sleep apnea issues, an additional database of providers would have to be used. As the study is cross-sectional in nature, the duration of the study is not an issue.

###### Ethical Issues

There are no ethical issues of concern.

### High Priority Future Research Needs Topic 5 What is the prognostic accuracy of clinical prediction rules (CPRs) to predict clinical outcomes?

#### Background

The CER found a low strength of evidence among seven studies that some clinical prediction rules (CPRs) may be useful in the prediction of a diagnosis of OSA. Ten different CPRs have been described. Nine CPRs have been used for the prediction of a diagnosis of OSA (using different criteria). Among those, the oropharyngeal morphometric model gave near perfect discrimination (area under the curve [AUC] = 0.996) to predict the diagnosis of OSA, and the pulmonary function data model had 100 percent sensitivity with 84 percent specificity to predict diagnosis of OSA. The remaining models reported lower sensitivities and specificities. Each model was deemed useful to predict the diagnoses of OSA by the individual study authors. However, while all the models were internally validated, external validation of these CPRs has not been conducted in the vast majority of the studies. None of the studies examined whether use of the CPR resulted in improved clinical outcomes.

#### Stakeholder Discussion

While the stakeholders considered the topic to be important, most of the discussion centered on the various factors that influence the diagnostic accuracy of CPRs, namely the setting (intercountry differences), level of care (primary, secondary, tertiary care) or source of data for initial screening assessment (self-report by patient, reporting by patient’s bed partner, or evaluation by health care provider).

#### Proposed Study Designs

We clarify that the aim of the topic is to evaluate the “prognostic” accuracy of existing CPRs, not to discuss the development of novel CPRs to predict OSA diagnosis by PSG. Specifically, the aim is to evaluate whether CPRs can determine who will experience a clinical outcome in the future. Different CPR thresholds will correspond to different counts of patients falling into different risk (or prognostic) groups based on clinical outcomes; the number of clinical events in the risk categories identified by the thresholds will vary depending on the actual value of the threshold used. Arguably, the most appropriate study design to address the prognostic accuracy of CPRs is a prospective observational study.

##### Prospective Observational Study

###### Value of Study Design

CPRs will be used to assign a “risk category” to each patient according to their likelihood of experiencing a future clinical outcome. Well-performing CPRs would be those that have high discriminatory ability and retain good calibration when they are evaluated in various settings. Discrimination pertains to whether the CPR is able to distinguish between categories of increasing risk of the experiencing the outcome. In the simple case of only two risk categories (low vs. high), the (predictive) sensitivity and the (predictive) specificity of a CPR would be a way to measure its discriminatory ability. Calibration pertains to whether the proportions predicted by the CPR in each risk category are “close” to the actual observed proportions. High calibration implies good discrimination, but good discrimination does not imply good calibration. For most clinical purposes, CPRs would be most informative if they have good calibration characteristics. However, for the purposes of this exposition, it is simpler to provide a sample size analysis for metrics that are related to the discriminatory ability of a CPR.

Prospective observational studies are best suited to assess the prognostic value of a CPR because they can study multiple risk factors of interest as well as clinical outcomes in a general patient population in whom the CPR will eventually be used, ensuring applicability and external validity of the results. The CPR would be applied to participants upon their entry to the cohort, and they would be followed to ascertain whether they experience an outcome or not. Another design is a nested case-control study, where all patients in a defined cohort who experience an event are designated as “cases” and are matched to a collection of “controls” (i.e., cohort participants who did not experience the outcome). A major advantage of a nested case-control study is that it allows an adequately powered post hoc analysis of prospectively collected data where the event rate is relatively rare.

The CPRs can be tested for their prognostic value for a range of outcomes, including sleep measures (which are quick and easy to collect), symptoms (e.g., sleepiness scales), clinical outcomes (e.g., mortality, cardiovascular disease, and diabetes; which would require decades-worth of followup), or their intermediate outcomes (e.g., blood pressure or measures of glucose and insulin homeostasis). Of note, the stakeholders were principally interested in the prognostic ability of CPRs on long-term clinical outcomes (instead of their surrogates).

###### Resource Use, Size, and Duration

If suitable databases are immediately available, one can perform a case-control study in a relatively short time, as there is no need to wait for followup. However, it may be difficult to reconstruct the CPR or identify people who match the setting of interest from a retrospective database, and therefore prospective collection of data may be unavoidable.

Prospective cohorts would take more time and effort compared to a case-control study built on an existing database. For example, when assessing incident cardiovascular disease or diabetes mellitus, the timeframe could be months or years. When assessing mortality outcomes, the timeframe could very well extend to decades. As mentioned above, already published studies of CPRs used short-term surrogate or intermediate markers in place of long-term clinical outcomes (for example, change in blood pressure for cardiovascular disease and change in fasting blood glucose for glucose intolerance).

Because of the substantial resources necessary for a prospective cohort study or a nested case-control study, it is probably not practical to design a study whose sole purpose is to assess the prognostic ability of CPRs. Instead, it would be preferable to incorporate the assessment of the prognostic performance of CPRs into a prospective cohort study in which assessment of prognostic performance will be one of several aims.

We performed exploratory power calculations to obtain approximate estimates of sample sizes for a nested case-control study or a cohort study. For simplicity, we assume that the goal is to enroll enough participants to estimate the discriminatory ability of a CPR (i.e., its sensitivity and specificity) with reasonable precision, operationally defined as a confidence interval length (upper minus lower bound) of no more than 0.10 (or 10 percent) for the sample estimates of both sensitivity and specificity:^*^ For example, if the sample sensitivity is 50 percent, the confidence interval would be no wider that 45 percent to 55 percent.^†^ The sample size calculations also depend on the prevalence of OSA in the setting of interest. Here, we assume that we are interested in applying the CPR to the general population, where the prevalence of OSA is approximately 10 percent.9

* Ideally, what constitutes “reasonable precision” would be defined based on additional information, and can differ according to the envisioned role of the CPR in clinical practice. The decision to use a length of 0.10 for the confidence interval is for illustration.

† The boundaries of the confidence intervals are not symmetric for proportions other than 0.50, but the desired length of the confidence interval is operationally defined to be 0.10.

Table 4 shows hypothetical sample size calculations for three scenarios of CPR sensitivity and specificity pairs. The first scenario is a case of low sensitivity (44 percent) and high specificity (85 percent), which was reported with a CPR based on age, sex, body mass index, reported snoring, and reported cessation of breathing during sleep.10 The second scenario is where the sensitivity and specificity were over 80 percent, seen with a CPR based on a multivariable apnea prediction questionnaire score and oximetry (sensitivity 83 percent, specificity 95 percent).11 The third scenario includes a high sensitivity (84 percent) but low specificity (39 percent) seen with a CPR based on a 24-item questionnaire and clinical characteristics.12

Table 4 Sample size estimates for various clinical scenarios of sensitivity and specificity with an assumed prevalence of 10 percent and an allowed variance of 10 percent in both sensitivity and specificity

Scenario | Sensitivity (%) | Specificity (%) | N_Sensitivity_^*^ | N_Specificity_^*^ | N_case-control_^†^ | N_cohort_^‡^
Low sensitivity High specificity | 44 | 85 | 379 | 196 | 575 | 3790
High sensitivity High specificity | 83 | 95 | 217 | 73 | 290 | 2170
High sensitivity Low specificity | 84 | 39 | 207 | 366 | 573 | 2070

* N needed to estimate sensitivity or specificity with a confidence interval that has length at most 0.10.

† This refers to a case control-study that would be conducted using existing records. We assume 1:1 ratio between cases and controls.

‡ N needed for Cohort Study: The number of people who have to be analyzed to ensure that we will have the necessary totals for estimating both sensitivity and specificity with the desirable precision. For example in scenario 1, since the prevalence is 10 percent, the number of people that you would have to screen to recruit 379 confirmed OSA patients is 379*10=3790 and the number of people that you would have to screen to recruit 196 people without OSA is 245. Since the larger number needed to screen for the given sensitivity would also satisfy the number needed to screen for the given specificity, the final number needed to screen is 3790.

###### Ability To Recruit

Patient recruitment should be straightforward and relatively simple, as patients are interested in knowing whether they have a condition that is known to cause complications and is associated with chronic disease outcomes.

###### Ethical Issues

The major ethical issue in this study design is the risk of a false negative report, resulting in denial of treatment to those patients who truly need it.

## Second-Tier Future Research Needs Topics

### Second-Tier Future Research Needs Topic 6 Indications (patient signs, symptoms, or other features) for appropriate home testing

#### Background

This topic was not directly addressed in the CER, except as the indications may have been incorporated into CPRs.

#### Stakeholder Discussion

The rationale for this topic discusses how the typical patient being evaluated for sleep apnea does not meet the criteria for eligibility into most trials, namely a high probability of OSA and a lack of significant factors that increase risk of other forms of sleep disordered breathing. Of interest is whether the home testing diagnostic studies are generalizable to more typical, lower risk patients.

### Second-Tier Future Research Needs Topic 7 Diagnostic approaches to OSA in obese and nonobese patients

#### Background

The subquestion to Key Question 1 of the CER addressed how different available tests compare in different subgroups of patients, including by body weight. The evidence was found to be insufficient to address this subquestion.

#### Stakeholder Discussion

The discussion revolved around the need to improve the diagnosis of, and refocus attention on, OSA patients who are not overweight, but instead have other causes for OSA.

## Other Future Research Needs Topics

### Other Future Research Needs Topic 8 Can PSG be skipped in making the diagnosis of sleep apnea?

### Other Future Research Needs Topic 9 What are the financial barriers to access to diagnosis?

### Other Future Research Needs Topic 10 Head-to-head comparisons of portable monitors, questionnaires, and prediction rules

### Other Future Research Needs Topic 11 Association between use of questionnaires and clinical outcomes

### Other Future Research Needs Topic 12 What are the available, objectively measured predictors of sleep apnea diagnosis?

### Other Future Research Needs Topic 13 What is consumer willingness to pay for screening, to identify consumer preferences for strategies to diagnose sleep apnea?

### Other Future Research Needs Topic 14 Value of scoring nasal flow limitation in recognizing mild OSA

### Other Future Research Needs Topic 15 Value of brain MRI in evaluating OSA patients

### Other Future Research Needs Topic 16 Randomized trials of phased testing

### Other Future Research Needs Topic 17 Value of using 4-phase rhinomanometry in recognition of patients with high nasal resistance and OSA

This topic was not considered to be high priority by any stakeholder.

### Other Future Research Needs Topic 18 Diagnostic approach to OSA in micrognathia and retrognathia

A stakeholder sent this topic to the EPC after the panel discussion ended.