# References

1 Balk EM, Moorthy D, Obadan NO, Patal K, Ip S, Chung M, Bannuru RR, Kitsios GD, Sen S, Iovin RC, Gaylor JM, D’Ambrosio C, Lau J. Diagnosis and Treatment of Obstructive Sleep Apnea in Adults. Comparative Effectiveness Review No. 32. (Prepared by Tufts Evidence-based Practice Center under Contract No. 290-2007-10055-1) AHRQ Publication No 11-EHC052-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
2 Agency for Healthcare Research and Quality. Future Research Needs Projects. 2010. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=521. Accessed September 6, 2011.
3 Balk EM, Chung M, Moorthy D, Chan JA, Patel K, Concannon TW, Ratichek SJ, Chang LKW. Diagnosis of Obstructive Sleep Apnea: Future Research Needs. Future Research Needs Paper No. 11. (Prepared by Tufts Evidence-based Practice Center under Contract No. 290-2007-10055 I) AHRQ Publication No 12-EHC031-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2012. www.effectivehealthcare.gov/reports/final.cfm.
4 Agency for Healthcare Research and Quality. Framework for Considering Study Designs for Future Research Needs (FRN) Draft Comparative Effectiveness Review. Rockville, MD. Agency for Healthcare Research and Quality. September. 2011. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=774.
5 Trikalinos TA, Ip S, Raman G, et al. Home Diagnosis of Obstructive Sleep Apnea-Hypopnea Syndrome, Technology Assessment. (Prepared by the Tufts-New England Medical Center Evidence-based Practice Center). Rockville, MD. Agency for Healthcare Research and Quality. 2007. www.cms.gov/determinationprocess/downloads/id48TA.pdf.
6 Young T, Palta M, Dempsey J, Skatrud J, Weber S, Badr S. The occurrence of sleep-disordered breathing among middle-aged adults. N Engl J Med. 1993;328:1230-1235. [pmid: 8464434].
7 Hallowell PT, Stellato TA, Petrozzi MC, et al. Eliminating respiratory intensive care unit stay after gastric bypass surgery. [erratum appears in Surgery. 2008 Feb;143(2):301]. Surgery. 2007;142:608-612. [pmid: 17950355].
8 Parthasarathy S, Haynes PL, Budhiraja R, et al. A national survey of the effect of sleep medicine specialists and American Academy of Sleep Medicine Accreditation on management of obstructive sleep apnea. [see comment]. Journal of Clinical Sleep Medicine. 2006;2:133-142. [pmid: 17557485].
9 Young T, Finn L, Peppard PE, et al. Sleep disordered breathing and mortality: eighteen-year follow-up of the Wisconsin sleep cohort. Sleep. 2008;31:1071-1078. [pmid: 18714778].
10 Rodsutti J, Hensley M, Thakkinstian A, et al. A clinical decision rule to prioritize polysomnography in patients with suspected sleep apnea. Sleep. 2004;27:694-699. [pmid: 15283004].
11 Gurubhagavatula I, Maislin G, Pack AI. An algorithm to stratify sleep apnea risk in a sleep disorders clinic population. American Journal of Respiratory & Critical Care Medicine. 2001;164(10 Pt 1):1904-9. [pmid: 11734444].
12 Rowley JA, Aboussouan LS, Badr MS. The use of clinical prediction formulas in the evaluation of obstructive sleep apnea. Sleep. 2000;23:929-938. [pmid: 11083602].