# Acknowledgements

## Stakeholder Panel

Elise Berliner, Ph.D.

Agency for Healthcare Research and Quality

Rockville, MD

Apostolos P. Dallas, M.D.

Virgina Tech-Carilion School of Medicine and Research Institute

Roanoke, VA

Carolyn M. D’Ambrosio, M.D., FCCP, DABSM

Director, The Center for Sleep Medicine

Associate Professor of Medicine

Tufts University School of Medicine

Tufts Medical Center

Boston, MA

Daniel J. Gottlieb, M.D., M.P.H.

Director, Sleep Disorders Center, VA

Boston Healthcare System

Associate Professor of Medicine, Boston

University School of Medicine

Boston, MA

Edward Grandi

Executive Director

American Sleep Apnea Association

Washington, DC

Christian Guilleminault M.D., D.Biol.

Sleep Medicine Division, Stanford University

Stanford, CA

Joseph A. Hanak, M.D.

Chief, Adult Physical Medicine and Rehabilitation

Tufts Medical Center

Boston, MA

Vishesh Kapur M.D., M.P.H.

Associate Professor of Medicine

University of Washington

Medical Director, UW Medicine Sleep Center

Seattle, WA

Sheri Katz, D.D.S.

President of the American Academy of Dental Sleep Medicine

Darien, IL

Meir Kryger M.D., FRCPC

Physician, Connecticut VA Healthcare System

Professor, Yale University School of Medicine

Hartford, CT

Atul Malhotra, M.D.

Associate Professor Medicine, Harvard Medical School

Medical Director, Sleep Disorders Research Program

Clinical Chief, Sleep Medicine Pulmonary & Critical Care and Sleep Medicine Divisions

Brigham and Women’s Hospital

Boston, MA

Tracy R. Nasca

Founder and Senior Vice President

Talk About Sleep, Inc.

Chaska, MN

Allan I. Pack, M.B.Ch.B., Ph.D.

The John Miclot Professor of Medicine

Chief, Division of Sleep Medicine

Director, Center for Sleep and Circadian Neurobiology

Perelman School of Medicine at the University of Pennsylvania

Philadelphia, PA

Andrew Scibelli, M.B.A., M.A.

Manager, Employee Health and Well-being

NextEra Energy, Inc.

Juno Beach, FL

Victor G. Villagra, M.D., FACP

Chief Medical Officer

National Rural Electric Cooperative Association

Arlington, VA

Thomas Weakley

Director of Operations Owner-Operator

Independent Drivers Association (OOIDA) Foundation, Inc.

Grain Valley, MO

Robert W. Zavoski, M.D., M.P.H.

Medical Director

Medical Care Administration

Connecticut Department of Social Services

Hartford, CT

An anonymous Medical Director.

An anonymous Federal agency stakeholder.