# Acronyms

AHI: Apnea-hypopnea index
AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review (on OSA, by Tufts EPC)1]
CPAP: Continuous positive airway pressure (device)
CPR: Clinical prediction rule
EPC: Evidence-based Practice Center
FRN: Future research need(s)
OSA: Obstructive sleep apnea
PSG: Polysomnography
QALY: Quality-adjusted life years
RCT: Randomized controlled trial