# Executive Summary^*^ * Please refer to the main report for references.

## Background

The current Future Research Needs (FRN) project was launched shortly after completion of the comparative effectiveness report (CER) on obstructive sleep apnea (OSA). OSA is an important public health issue, due to the considerable mortality and morbidity associated with the condition. The commonly used methods for diagnosing and treating OSA are cumbersome, resource-intensive, and often inconvenient for the patient. The Tufts EPC conducted a CER on diagnostic tools, characteristics of OSA that are predictive of poor outcomes, and treatments for OSA. For the purpose of the FRN process, the original OSA CER was divided into two overarching sections: diagnosis and treatment. This document describes the FRN for diagnosis of OSA; an accompanying parallel report describes the FRN for treatment. For the most part, the Background, Methods, and description of the challenges are nearly identical between the two reports.

Figure A is an analytic framework to visualize areas of the systematic review in which evidence gaps were identified. Table A summarizes the evidence gaps identified in our review of the diagnosis of OSA in adults (the CER’s Key Questions 1–4). These gaps in the evidence review limited the ability to make conclusions on the questions asked; thus they formed the initial FRN topics.

Figure A Analytic framework for the diagnosis of obstructive sleep apnea in adults with evidence gaps

CVD = cardiovascular disease; D = study design; IC = intervention and comparator; KQ = Key Question; NIDDM = noninsulin dependent diabetes mellitus; O = outcome; P = population; QoL = quality of life

The analytic framework above highlights the evidence gaps in red that were identified as affecting the conclusions for the respective Key Questions in the CER. The alphanumeric code for the gaps corresponds to the detailed gaps that are listed in Table 1. The first number of the code corresponds to the key question, the following letters represent the PICOD domains, and the last numerical corresponds to the number on the list for that particular Key Question and domain. Where there is only one gap identified, the last number is dropped. Grayed out portions of the analytic framework are treatment-related questions that are covered in the companion report.3

Figure A. Analytic framework for the diagnosis of obstructive sleep apnea in adults with evidence gaps. Figure A summarizes the evidence gaps identified in our review of the diagnosis of obstructive sleep apnea in adults. The original analytic framework in the comparative effectiveness review was modified to highlight the relevant key questions (1–4) and evidence gaps within the context of PICOD (patient populations, interventions, comparators, outcomes, and study designs of interest). With reference to the coding using in Table A, the arrow linking treatment with health and related outcomes (key question 1–4) is associated with evidence gaps 1IC1, 1IC2, 1IC3, 1IC4, 2IC1, 3IC1, 4IC1, 1O, 2O, 3O, 4O, and 5O. The arrow linking patients with symptoms suggestive of sleep apnea and patients with a diagnosis of sleep apnea is associated with evidence gaps regarding study designs: 1D1, 1D2, 1D3, 1D4, 2D1, 2D2, 3D1, and 3D2. Evidence gaps 1P, 2P, 3P and 4P are shown near the population of interest, that is, patients with symptoms suggestive of sleep apnea and patients with a diagnosis of sleep apnea.

Table A Evidence gaps affecting conclusions for the Key Questions

Key Question | Category | Evidence Gap
Key Question 1. How do different available tests compare in their ability to diagnose sleep apnea in adults with symptoms suggestive of disordered sleep? Key Question 1a. How do these tests compare in different subgroups of patients, based on: race, sex, body mass index, existing noninsulin dependent diabetes mellitus, existing cardiovascular disease, existing hypertension, clinical symptoms, previous stroke, or airway characteristics? | Population | 1P: No subgroup analyses available for any test - none of the studies explicitly evaluated the monitors in patients with important comorbidities such as chronic lung disease, or congestive heart failure.
| Intervention/Comparator | 1IC1: No head-to-head comparisons of portable monitors, questionnaires, and prediction rules. 1IC2: Insufficient data to make conclusions about the following questionnaires: STOP, STOP-Bang, ASA checklist, Hawaii Sleep Questionnaire. 1IC3: No tests based on severity of symptoms. 1IC4: No standardized method of testing used.
| Outcomes | 1O: No analyses of clinical outcomes, including response to treatment or process outcomes.
| Design | 1D1: Incomplete reporting and inadequate analyses were common. 1D2: Few high quality studies with little susceptibility to bias. 1D3: The studies did not allow us to adequately assess any issues related to night-to-night variation. 1D4: Verification bias (i.e. not testing all participants with all the devices that are being compared) is seen in many studies. 1D5: Most of the studies performed at academic/research centers. It is not clear how the results would generalize to the general population.
Key Question 2. How does phased testing (screening tests or battery followed by full test) compare to full testing alone? | Population | 2P: Studies on a general population of people with OSA are needed.
Key Question 2. How does phased testing (screening tests or battery followed by full test) compare to full testing alone? | Intervention/Comparator | 2IC: No studies directly address this question.
Key Question 2. How does phased testing (screening tests or battery followed by full test) compare to full testing alone? | Outcomes | 2O: No analyses of clinical outcomes were done.
Key Question 2. How does phased testing (screening tests or battery followed by full test) compare to full testing alone? | Design | 2D1: One available study subject to verification bias. 2D2: Studies evaluating the appropriateness of tests based on patient characteristics and severity of their symptoms were not available.
Key Question 3. What is the effect of preoperative screening for sleep apnea on surgical outcomes? | Population | 3P: More studies on general surgical patients are needed.
Key Question 3. What is the effect of preoperative screening for sleep apnea on surgical outcomes? | Intervention/Comparator | 3IC: A broad range of screening tools, including questionnaires; need to be evaluated against PSG.
Key Question 3. What is the effect of preoperative screening for sleep apnea on surgical outcomes? | Outcomes | 3O: Long-term outcomes were not evaluated.
Key Question 3. What is the effect of preoperative screening for sleep apnea on surgical outcomes? | Design | 3D1: No randomized trials address this question. 3D2: Selection biases of major concern in available studies.
Key Question 4. In adults being screened for obstructive sleep apnea, what are the relationships between apnea-hypopnea index or oxygen desaturation index, and other patient characteristics with long-term clinical and functional outcomes? | Population | 4P: Further studies evaluating the link between apnea-hypopnea index, and diabetes mellitus and hypertension are needed.
| Intervention/Comparator | 4IC: Only AHI was well-studied, not other indices and patient characteristics.
| Outcomes | 4O: Other than all-cause mortality, clinical outcomes are understudied.

AHI = apnea-hypopnea index; ASA = American Society of Anesthesiologists; OSA = obstructive sleep apnea; PSG = polysomnography; STOP = Snoring; STOP-Bang = STOP with body mass index, age, neck circumference, and sex variables

## Methods

### Stakeholder Involvement

FRN topics nominated for prioritization were identified based on recommendations from the original CER and through an iterative process utilizing a diverse stakeholder panel. After a formal recruitment process, participating panelists were asked to review, discuss and nominate for prioritization CER-derived FRN topics, as well as submit additional topics for FRN consideration. The panel consisted of patient advocates, providers, purchasers, payers, policymakers, researchers and product makers, representing the full range of stakeholders who may use research evidence in health care and public health decisionmaking.

### Use of Microsoft^®^ SharePoint

The Evidence-based Practice Center (EPC) developed a secure, password-protected Microsoft^®^ SharePoint Web site primarily to host the online stakeholder discussions of the FRN topics. The SharePoint Web site also functioned as a platform for Tufts EPC staff to post project announcements and reference documents.

Throughout the open discussion period, stakeholders could use SharePoint to submit new FRN topics; a direct email to EPC staff was also an option. All stakeholder-submitted topics were reviewed and refined by the EPC. These topics, along with the CER-derived FRN topics, were posted by EPC staff on the SharePoint Web site for stakeholder discussion.

Each FRN topic was posted as a separate “discussion board.” For their discussions, stakeholders were asked to consider four dimensions of need related to the proposed topic: (1) importance; (2) desirability of research/duplication; (3) feasibility; and (4) potential impact. Stakeholder participation was encouraged and monitored throughout the discussion period, and discussion boards were moderated daily by Tufts EPC staff to ensure appropriateness and relevance of all comments.

### Approach to Prioritization

After the close of the online discussion period, stakeholders were asked to identify up to five FRN topics—considering the topic’s importance, desirability, feasibility and potential impact—that were of highest priority and that met the Effective Health Care Program Selection Criteria. Nomination was conducted by email and individual phone calls. After nomination, the EPC grouped similar topics into overarching topics and categorized them into four groups: (1) high-priority topics; (2) second-tier priority topics; (3) topics of little interest to stakeholders; and (4) topics not meeting Effective Health Care Program appropriateness criteria.

### Research Question Development and Considerations for Potential Research Design

For each “high-priority” FRN topic, EPC staff considered the range of study designs that would best address the topic. To determine candidate study designs, the feasibility of the study designs, and sample size calculations, we followed the structure laid out in the Future Research Needs document Framework for Considering Study Designs for Future Research Needs.4 For each topic, we described our assumptions about the most appropriate PICOD criteria (Population, Intervention, Comparator, Outcomes, study Design), in particular describing the advantages and disadvantages of various potential research designs. We specifically considered the feasibility of the research questions focusing on potential sample size, time, and recruitment issues.

## Results

Table B lists the final FRN topics.

Table B List of future research needs topics

High-Priority Future Research Needs Topics
1. Age- and gender-specific criteria for defining the OSA syndrome (and abnormal breathing)
2. Effect of routine (or selected) preoperative screening for sleep apnea
3. Cost-effectiveness analysis of a management strategy (diagnosis of symptomatic or high-risk patients through treatments of patients diagnosed with OSA), specifically for patients with mild to moderate disease severity
4. Value of having a sleep medicine specialist involved in the diagnosis of OSA (in addition to or instead of a nonspecialist)
5. What is the prognostic accuracy of clinical prediction rules (CPRs) to predict clinical outcomes?
Second-Tier Future Research Needs Topics
6. Indications (patient signs, symptoms, or other features) for appropriate home testing
7. Diagnostic approaches to OSA in obese and nonobese patients
Other Future Research Needs Topic
8. Can PSG be skipped in making the diagnosis of sleep apnea?
9. What are the financial barriers to access to diagnosis?
10. Head-to-head comparisons of portable monitors, questionnaires, and prediction rules
11. Association between use of questionnaires and clinical outcomes
12. What are the available, objectively-measured predictors of sleep apnea diagnosis?
13. What is consumer willingness-to-pay for screening, to identify consumer preferences for strategies to diagnose sleep apnea?
14. Value of scoring nasal flow limitation in recognizing mild OSA
15. Value of brain MRI in evaluating OSA patients
16. Randomized trials of phased testing
17. Value of using 4-phase rhinomanometry in recognition of patients with high nasal resistance and OSA
18. Diagnostic approach to OSA in micrognathia and retrognathia

### High-Priority Future Research Needs Topic 1 Age- and gender-specific criteria for defining the OSA syndrome (and abnormal breathing)

This overarching topic was addressed in general terms in the Introduction of the CER, but it was not a Key Question in the report. A Technology Assessment preceding the CER concluded that most experts consider laboratory-based PSG as the reference method to identify people with apnea-hypopnea index (AHI) suggestive of OSA. However, this does not mean that facility-based PSG is an error-free “gold standard” for measuring (abnormal) breathing, or that facility-based PSG measurements of breathing are generally sufficient for defining the OSA syndrome. The stakeholders stated that there is a need for a new definition of the OSA syndrome that identifies individuals with breathing abnormalities during sleep who have or are at risk of developing clinical sequelae because of their exposure to sleep-disordered breathing. The aim of this future research need topic is to identify age- and gender-specific criteria for defining individuals who are at increased health risk because of abnormal breathing during sleep (OSA syndrome); it is not to discuss the clinical utility of (yet undefined) age-and gender-specific diagnostic criteria.

#### Prospective Cohort Study

Prospective longitudinal cohort studies are the most informative studies to assess predictors of natural history outcomes (e.g., age and sex as criteria for OSA). A well-designed prospective study will be less biased than a retrospective database analysis. Randomized trials of interventions generally do not provide better data to assess predictors of natural history outcomes. We suggest a prospective cohort study of people selected from the general population to associate measurements of breathing with a battery of short-term pathophysiological measurements that distinguish people whose breathing patterns have immediate physiological impact, from those whose breathing patterns do not have measurable functional sequelae. Multivariable analyses that control for potential confounders, such as comorbidity and body mass index, should be performed to evaluate the relationship between measurements of breathing (e.g., AHI scores) and functional outcomes by sex and age groups. It should be noted that the definitive definition of OSA will remain unclear because whether the functional outcomes are good proxy markers for clinical outcomes will likely remain unknown. With long-term followup, the proposed cohort study can also provide natural history data. Any subsequent treatments and additional diagnostic testing should also be recorded as these data could inform the clinical utility of the age- and gender-specific diagnostic criteria.

### High-Priority Future Research Need Topic 2 Effect of routine (or selected) preoperative screening for sleep apnea

The CER found insufficient evidence to address this topic. The stakeholders’ discussions centered on the anecdotal nature of the evidence regarding perioperative risks in patients with undiagnosed OSA. Other issues that were identified as lacking evidence related to patient risk characteristics, the type of surgery, and the outcomes of interest. There is a need to evaluate the value of routine (or selected) preoperative screening for OSA, to assess whether it is justified as a part of routine preoperative assessment.

#### Randomized Controlled Trials (RCTs)

A randomized comparison of screening for OSA with extended anesthesia care when appropriate versus no screening with routine anesthesia care would provide information for effectiveness of the screening protocol. The design of choice would likely be a multicenter cluster-randomized trial, where whole centers would be randomized to screen patients or not. The advantage of using a cluster-randomized trial is that there is a minimal risk of protocol deviation if active OSA screening is performed as part of a center’s clinical protocols. There would also be little risk of cross-contamination, of OSA screening to patients who had been randomized to not receive screening. It is also likely that recruitment and randomization will be logistically easier if it is done at the center level, rather than at the patient level within a center. Use of validated screening questionnaires and the shorter perioperative follow up period make it easier to recruit. However, since the event rate for postoperative complications is low due to the advances in perioperative care, the required sample sizes are number in the thousands, ranging from 2000 to 100,000. These could result in the use of large resources in terms of cost, time and effort, and the decision to use these resources for conducting trials has to be balanced against the benefit of screening on postoperative complications. Loss to followup should be rare if an adequate system were in place to follow patients. If a convincing argument can be made that a continuous outcome could be an adequate proxy outcome for postoperative complications, then it is likely that a smaller sample size would be needed for adequate power for this outcome. However, it is currently unclear than any continuous outcome would be a convincing proxy.

#### Observational Studies

Observational studies, such as those that exist, are likely to be fundamentally flawed. In normal clinical practice, preoperative patients who undergo testing for OSA will always be greatly different than unscreened patients. However, these studies would be less resource-intensive than a trial. The validity of the data collected using a flawed study design detracts from the benefit gained by decreased resource utilization.

### High-Priority Future Research Needs Topic 3 Cost-effectiveness analysis of a management strategy (diagnosis of symptomatic or high-risk patients through treatments of patients diagnosed with OSA), specifically for patients with mild to moderate disease severity

Cost-effectiveness analysis allows the comparison of different interventions on similar benefit, cost and utility scales. Benefit and cost estimates can have both internal and external validity. The objective of this FRN is to establish better evidence about the costs and benefits of alternative diagnostic strategies for individual patients with mild to moderate disease severity. The companion report presents a similar discussion on the costs and benefits of alternative treatment strategies.

#### Systematic Review

Cost-effectiveness analyses were not addressed by the CER. Conducting a systematic review may be the first step to ascertain the level of existing evidence.

#### Cost–Benefit Analysis

A quality-adjusted cost–benefit analysis is recommended, comparing the incremental costs and benefits of different diagnostic strategies to each other. Benefit, utility, and cost estimates may be derived from previous clinical studies data, where available, and otherwise from observational data. These estimates should include clinical, work-related, accident, and quality of life outcomes. Out-of-pocket patient costs should also be included in cost estimates. A societal perspective should be assumed in the main analysis and the patient perspective in a sub-analysis. A variety of diagnostic strategies should be considered, including but not limited to PSG in everyone, diagnostic algorithms and clinical prediction rules, portable monitoring, and phased testing. Other tests could include four-phase rhinomanometry and brain magnetic resonance imaging. Because a cost-effectiveness analysis can draw from previously collected data, the cost, size and duration of such studies can be limited. However, as discussed by the stakeholders, it may be challenging to gather all the relevant data.

### High-Priority Future Research Needs Topic 4 Value of having a sleep medicine specialist involved in the diagnosis of OSA

Increasingly patients with OSA are being diagnosed by primary care providers. Home studies have allowed the primary care physician to bypass the sleep center altogether, and national companies have started marketing the use of home studies to primary care providers.

#### Systematic Review

The CER did not address the effect of having different specialists involved in care, thus a systematic review may be the first step to ascertain the level of existing evidence.

#### Analyzing Claims Data

Analyzing claims data provided by an insurance provider or a health care system, such as from deidentified Medicare and/or Medicaid claims data, could help to ascertain cost differences with use of a specialist. While this approach would be able to provide a large sample of patients from diverse geographic locations, it would not be a controlled analysis.

#### Post Hoc Analysis of Existing Trials

Another study option would be to review existing studies and analyze any available information on diagnosis by a sleep specialist versus diagnosis by a nonspecialist. This approach may require additional unpublished data from study authors.

#### Survey of Providers

A cross-sectional survey of providers would provide an in-depth view of issues associated with using a sleep specialist in the diagnosis of OSA. However, the size of the survey would be limited by participation rates, and the cross-sectional design would not be able to answer issues of causation.

### High-Priority Future Research Needs Topic 5 What is the prognostic accuracy of clinical prediction rules to predict clinical outcomes?

The CER found a low strength of evidence among seven studies that some clinical prediction rules (CPRs) may be useful in the prediction of a diagnosis of OSA. However, none of the studies examined this topic, namely whether use of a CPR resulted in improved clinical outcomes. The aim of the topic is to evaluate the “prognostic” accuracy of existing CPRs, to evaluate, whether CPRs can determine who will experience a clinical outcome in the future. Different CPR thresholds will correspond to different counts of patients falling into different risk (or prognostic) groups based on clinical outcomes; the number of clinical events in the risk categories identified by the thresholds will vary depending on the actual value of the threshold used. Arguably, the most appropriate study design to address the prognostic accuracy of CPRs is a prospective observational study.

#### Prospective Observational Study

Prospective observational studies are best suited to assess the prognostic value of a CPR because they can study multiple risk factors of interest as well as clinical outcomes in a general patient population in whom the CPR will eventually be used, ensuring applicability and external validity of the results. The CPR would be applied to participants upon their entry to the cohort, and they would be followed to ascertain whether they experience an outcome or not. Another design is a nested case-control study, where all patients in a defined cohort who experience an event are designated as “cases” and are matched to a collection of “controls” (i.e., cohort participants who did not experience the outcome). A major advantage of a nested case-control study is that it allows an adequately powered post hocanalysis of prospectively collected data where the event rate is relatively rare. If suitable databases are immediately available, one can perform a case-control study in a relatively short time, as there is no need to wait for followup. However, it may be difficult to reconstruct the CPR or identify people who match the setting of interest from a retrospective database, and therefore prospective collection of data may be unavoidable. Prospective cohorts would take more time and effort compared to a case-control study built on an existing database. For example, when assessing incident cardiovascular disease or diabetes mellitus, the timeframe could be months or years. When assessing mortality outcomes, the timeframe could very well extend to decades. Because of the substantial resources necessary for a prospective cohort study or a nested case-control study, it is probably not practical to design a study whose sole purpose is to assess the prognostic ability of CPRs. Instead, it would be preferable to incorporate the assessment of the prognostic performance of CPRs into a prospective cohort study in which assessment of prognostic performance will be one of several aims. For different scenarios of using CPRs with differential sensitivity and specificity pairs, the number of subjects that need to be studies ranges in the hundreds for nested case control studies to a few thousands for prospective cohorts. Patient recruitment should be straightforward and relatively simple, as patients are interested in knowing whether they have a condition that is known to cause complications and is associated with chronic disease outcomes.

## Discussion

We implemented a Web-based discussion board in preference over a series of teleconferences because of what we believed would be advantages of the online approach. These include: greater flexibility for stakeholders; full participation by all stakeholders in all discussions; a full record of all discussions; less time expenditure by stakeholders; and less resource expenditure by EPC staff. However, we encountered low participation rate of stakeholders during most stages of the project. In contrast, conducting a 1.5-hour teleconference for three consumer stakeholders produced six topic nominations, highlighting the difference in impact between the two communication platforms. Overall, although SharePoint offered the convenience of asynchronous collaboration it seemed to lack appropriate incentives to engage stakeholders.

Several possible solutions exist for these problems, including reducing the number of stakeholders; reverting to conducting a series of teleconferences; using focus groups to allow a full, simultaneous discussion of each topic; combining teleconferences with online discussions; or numerous other similar approaches. Regardless of which type of discussion is held, there may be advantages to limiting the size of the stakeholder panel and to choose stakeholders who show enthusiasm in joining the panel and participating in discussions.

The stakeholder discussion identifying FRN topics on diagnosis of OSA highlights the vast field of research that could potentially be done in this area. Three out of the five nominated topics fell outside the purview of the questions addressed in the CER. The scope of the original CER was focused on the use of portable tools and screening, phased testing and preoperative screening, and the relationships of OSA indices to clinical outcomes. Notably, the stakeholders considered a range of topics broader than the CER’s Key Questions regarding diagnosis of OSA to be important for future research.

In summary, the online Web site discussion of numerous topics by a large stakeholder panel was only moderately successful. Various approaches to improve participation and discussion are possible, including increased use of teleconferences, restricting the size and members of the stakeholder panel, and other approaches. More experience with different approaches is needed.