# Background

## Context

Comparative Effectiveness Reviews (CER)—systematic reviews of existing research on the effectiveness, comparative effectiveness, and comparative harms of different health care interventions—are intended to provide relevant evidence to inform real-world health care decisions for patients, providers, and policymakers. In addition to synthesizing the evidence, CERs also identify the gaps in evidence that limit the ability to answer the key research questions. As part of an effort beginning in 2010, the Agency for Healthcare Research and Quality (AHRQ) supports its Evidence-based Practice Centers (EPCs) to work with various stakeholders to further develop and prioritize the future research needed by decisionmakers.2 This process is new, and the methods to delineate future research needs (FRN) are not yet fully developed. The current report describes the first experience of the Tufts EPC in a stakeholder-driven process to identify and nominate for prioritization FRN topics (other than a pilot process with a limited involvement of a small number of stakeholders).

The FRN document is intended to inform and support researchers and those who fund research to ultimately enhance the body of comparative effectiveness evidence so that it is useful for decisionmakers. This document describes the process of developing a prioritized list of research needs with considerations of the advantages and disadvantages of various potential research designs to help researchers and funders develop future research proposals or solicitations, respectively. This process begins with identification of evidence gaps from the original CER, followed by the addition of other areas potentially requiring further research, nomination for prioritization of these evidence gaps by stakeholders, and development of potential study designs for the highest priority topics. Although researchers and funders of research are the end-users of the report, the resulting research is meant to improve health care decisions; therefore, the stakeholders for this process include patients, clinicians, research investigators, payers, and policymakers.

The current FRN project was launched shortly after completion of the CER on obstructive sleep apnea (OSA). OSA is an important public health issue, due to the considerable mortality and morbidity associated with the condition. The commonly used methods for diagnosing and treating OSA are cumbersome, resource intensive, and often inconvenient for the patient. The Tufts EPC conducted a CER on diagnostic tools, characteristics of OSA that are predictive of poor outcomes, and treatments for OSA.1 For the purpose of the FRN process, the original OSA CER was divided into two overarching sections: diagnosis and treatment. This document describes the FRN for diagnosis of OSA; an accompanying parallel report describes the FRN for treatment.3 For the most part, the Background, Methods, and description of the challenges are nearly identical between the two reports.

Figure 1 is an analytic framework to visualize areas of the systematic review in which evidence gaps were identified. Table 1 summarizes the evidence gaps identified in our review of the diagnosis of OSA in adults (the CER’s Key Questions 1–4). These gaps in the evidence review limited the ability to make conclusions on the questions asked; thus they formed the initial FRN topics.

Figure 1 Analytic framework for the diagnosis of obstructive sleep apnea in adults with evidence gaps

CVD = cardiovascular disease; D = study design; IC = intervention and comparator; KQ = Key Question; NIDDM = noninsulin dependent diabetes mellitus; O = outcome; P = population; QoL = quality of life;

The analytic framework above highlights the evidence gaps in red that were identified as affecting the conclusions for the respective Key Questions in the CER. The alphanumeric code for the gaps corresponds to the detailed gaps that are listed in Table 1. The first number of the code corresponds to the Key Question, the following letters represent the PICOD domains, and the last numerical corresponds to the number on the list for that particular Key Question and domain. Where there is only one gap identified, the last number is dropped. Grayed out portions of the analytic framework are treatment-related questions that are covered in the companion report.3

Figure 1. Analytic framework for the diagnosis of obstructive sleep apnea in adults with evidence gaps. Figure 1 summarizes the evidence gaps identified in our review of the treatment of obstructive sleep apnea in adults. The original analytic framework in the comparative effectiveness review was modified to highlight the relevant key questions (1–4) and evidence gaps within the context of PICOD (patient populations, interventions, comparators, outcomes, and study designs of interest). With reference to the coding using in Table A, the arrow linking treatment with health and related outcomes (key question 1–4) is associated with evidence gaps 1IC1, 1IC2, 1IC3, 1IC4, 2IC1, 3IC1, 4IC1, 1O, 2O, 3O, 4O, and 5O. The arrow linking patients with symptoms suggestive of sleep apnea and patients with a diagnosis of sleep apnea is associated with evidence gaps regarding study designs: 1D1, 1D2, 1D3, 1D4, 2D1, 2D2, 3D1, and 3D2. Evidence gaps 1P, 2P, 3P and 4P are shown near the population of interest, that is, patients with symptoms suggestive of sleep apnea and patients with a diagnosis of sleep apnea.

Table 1 Evidence gaps affecting conclusions for the Key Questions

Key Question | Category | Evidence Gap
Key Question 1. How do different available tests compare in their ability to diagnose sleep apnea in adults with symptoms suggestive of disordered sleep? Key Question 1a. How do these tests compare in different subgroups of patients, based on: race, sex, body mass index, existing noninsulin dependent diabetes mellitus, existing cardiovascular disease, existing hypertension, clinical symptoms, previous stroke, or airway characteristics? | Population | 1P: No subgroup analyses available for any test—none of the studies explicitly evaluated the monitors in patients with important comorbidities such as chronic lung disease, or congestive heart failure.
| Intervention/Comparator | 1IC1: No head-to-head comparisons of portable monitors, questionnaires, and prediction rules. 1IC2: Insufficient data to make conclusions about the following questionnaires: STOP, STOP-Bang, ASA checklist, Hawaii Sleep Questionnaire. 1IC3: No tests based on severity of symptoms. 1IC4: No standardized method of testing used.
| Outcomes | 1O: No analyses of clinical outcomes, including response to treatment or process outcomes.
| Design | 1D1: Incomplete reporting and inadequate analyses were common. 1D2: Few high quality studies with little susceptibility to bias. 1D3: The studies did not allow us to adequately assess any issues related to night-to-night variation. 1D4: Verification bias (i.e. not testing all participants with all the devices that are being compared) is seen in many studies. 1D5: Most of the studies performed at academic/research centers. It is not clear how the results would generalize to the general population.
Key Question 2. How does phased testing (screening tests or battery followed by full test) compare to full testing alone? | Population | 2P: Studies on a general population of people with OSA are needed.
Key Question 2. How does phased testing (screening tests or battery followed by full test) compare to full testing alone? | Intervention/Comparator | 2IC: No studies directly address this question.
Key Question 2. How does phased testing (screening tests or battery followed by full test) compare to full testing alone? | Outcomes | 2O: No analyses of clinical outcomes were done.
Key Question 2. How does phased testing (screening tests or battery followed by full test) compare to full testing alone? | Design | 2D1: One available study subject to verification bias. 2D2: Studies evaluating the appropriateness of tests based on patient characteristics and severity of their symptoms were not available.
Key Question 3. What is the effect of preoperative screening for sleep apnea on surgical outcomes? | Population | 3P: More studies on general surgical patients are needed.
Key Question 3. What is the effect of preoperative screening for sleep apnea on surgical outcomes? | Intervention/Comparator | 3IC: A broad range of screening tools, including questionnaires; need to be evaluated against PSG.
Key Question 3. What is the effect of preoperative screening for sleep apnea on surgical outcomes? | Outcomes | 3O: Long-term outcomes were not evaluated.
Key Question 3. What is the effect of preoperative screening for sleep apnea on surgical outcomes? | Design | 3D1: No randomized trials address this question. 3D2: Selection biases of major concern in available studies.
Key Question 4. In adults being screened for obstructive sleep apnea, what are the relationships between apnea-hypopnea index or oxygen desaturation index, and other patient characteristics with long-term clinical and functional outcomes? | Population | 4P: Further studies evaluating the link between apnea-hypopnea index, and diabetes mellitus and hypertension are needed.
| Intervention/Comparator | 4IC: Only AHI was well studied, not other indices and patient characteristics.
| Outcomes | 4O: Other than all-cause mortality, clinical outcomes are understudied.

AHI = apnea-hypopnea index; ASA = American Society of Anesthesiologists; OSA = obstructive sleep apnea; PSG = polysomnography; STOP = snoring; STOP-Bang = STOP with body mass index, age, neck circumference, and sex variables.