# Appendixes

Appendix A AHRQ’s Effective Health Care Program Selection Criteria for New Research