# Results

## Research Needs

A total of seven research gaps were identified through a combination of the BCBSA TEC draft HSCT CER and conversations with the key informants (including patient advocates). These gaps are crosscutting in that they apply to more than one indication for HSCT. The gaps are:

- Long-term consequences of HSCT, measured by overall survival, functional measures, quality of life, and adverse effects
- Mitigation of long-term adverse effects by changes in regimen, including reduced intensity approaches, and changes in subsequent medical or psychosocial intervention
- Role of novel therapies for HSCT in altering short-term adverse effects and the long-term effects of these therapies. Such approaches include:
  ○ novel cellular therapies (such as natural-killer-cell therapy), and
  ○ immunomodulatory therapies (including vaccine therapy).
- Multicenter collaboration to increase accrual of patients and systematize outcome reporting
- Effectiveness of survivorship planning on long term, comprehensive followup and outcomes
- Impact on outcomes of a “family-centered” approach to transplantation. Advocates of children who have undergone HSCT transplantation defined such an approach as including:
  ○ emotional and psychosocial counseling for the family with a special attention on donor and nondonor siblings,
  ○ information to share with caregivers and peers, and
  ○ tools rather than only a large amount of information for navigating the complexities of the medical system and medication management.
- Uniform reporting of outcome data to allow patient comparison of HSCT outcomes by transplant center

As stated in the Methods section, we attempted to have the Key Informants rank the research gaps and generate Key Questions online prior to a teleconference. Only half of the group responded to the online request. Therefore, on the teleconference, the Key Informants discussed the evidence gaps and appropriate Key Questions. Both the preliminary results based on the five responses and the more complete results based on eight responses elicited after the conference call are found in Appendix H. During the teleconference (#2), the Key Informants discussed the relative importance of each of the seven identified gaps, and then addressed the important Key Questions within each gap. After the teleconference (#2), followup phone calls were completed with two members not on the call, and one additional Key Informant submitted rankings, bringing the total to eight. The rankings from one original Key Informant were never received. The EPC generated the final ranking of research gaps taking all Key Informant comments into account. In the final ranking of the research gaps based on feedback from the key informants on gaps where research was known to be underway were removed from the listing.

The final four research gaps, in priority order are:

1. Mitigation of long-term adverse effects by changes in regimen, including reduced intensity approaches, and changes in subsequent medical or psychosocial intervention.
2. Role of novel therapies for HSCT in altering short-term adverse effects and the long-term effects of these therapies. Such approaches include:
  a. novel cellular therapies (such as natural-killer-cell therapy), and
  b. immunomodulatory therapies (including vaccine therapy).
3. Impact on outcomes of a “family-centered” approach to transplantation. Advocates of children who have undergone HSCT transplantation defined such an approach as including:
  a. emotional and psychosocial counseling for the family with a special attention on donor and nondonor siblings,
  b. information to share with caregivers and peers, and
  c. tools rather than only a large amount of information for navigating the complexities of the medical system and medication management.
4. Effectiveness of survivorship planning on long-term, comprehensive followup and outcomes.

Within Gap 1, mitigation of long-term effects by changes in regimen and changes in subsequent medical or psychosocial intervention, the Key Informants were particularly interested in addressing the impact of post-transplant psychological disorders in pediatric HSCT recipients and families. Patient advocates initiated the emphasis on psychosocial support and their view was embraced by all the key informants. Moreover, the matter of changes in regimen was of less interest, as there is ongoing research in the area. It is estimated that as many as 41 percent6, 7 of survivors of HSCT have persistent PTSD symptoms for up to 10 years post-transplant.8, 9 Further, parents of pediatric transplant recipients also have high levels of PTSD.10 In 2010, DuHamel and colleagues reported that a brief telephone-administered cognitive behavioral therapy intervention for HSCT survivors was effective in reducing illness-related PTSD and general distress.11 Addressing this gap would add to the minimal literature specifically addressing the psychosocial needs of pediatric patients and families post-HSCT.

Gap 2 addresses ways to reduce the adverse effects of HSCT. Our Key Informant panel believed this to be the future of transplantation as novel approaches are discovered. They kept the Key Questions broad for the purposes of this report, as they felt that data are too sparse to point to one focus area.

Gap 3, impact on outcomes of a “family-centered” approach to transplantation, was proposed by the patient advocates and endorsed by the combined panel. Families of pediatric HSCT recipients are asked to endure a great deal over time and to acquire extraordinary new skills to care for their child. As the medical home model takes shape, families of pediatric HSCT recipients are asking whether the model might work for them. According to the Joint Principles of the Patient-Centered Medical Home,12 a patient-centered medical home should have a personal physician, physician-directed medical practice, whole person orientation, coordinated care, quality and safety, enhanced access, and adequate payment. The number of autologous transplants in the U.S. has steadily increased since 2000, and allogeneic transplants from unrelated donors surpassed the number of allogeneic transplants from related donors after 2007.^13^ With the rising number of affected families, addressing this gap could have a large and beneficial impact on how these children and their families receive care.

Finally, Gap 4 focuses on the specifics of survivorship planning or long-term care planning. Cancer advocacy groups and many cancer centers have taken on the task of aiding patients develop these plans. At issue is whether the creation of such a formal document affects outcomes. The National Academies Press published a book called Implementing Cancer Survivorship Care Planning.14 They advocate the implementation of survivorship planning, but acknowledged that while it could reasonably be expected that survivorship planning would improve outcomes, prospective research is needed to confirm or refute this assumption. Addressing Gap 4 would begin to answer this question specifically for pediatric patients undergoing HSCT.

Gaps not included in the prioritized list include (1) long-term effects of HSCT measured by overall survival, functional measures, quality of life, and adverse effects; (2) multicenter collaboration to increase accrual of patients and systematize outcome reporting; and (3) uniform reporting of outcome data to allow patient/caregiver comparison of HSCT outcomes by transplant center. These gaps were assigned lower priority than the others not due to their relative importance, but because other groups are working on these issues. First, the Pediatric Blood and Marrow Transplant Consortium (PBMTC) is currently working on and has generated multiple Key Questions to specifically target and investigate long-term effects.15 The Key Informants stated that while multicenter collaboration is encouraged and mechanisms are in place, low levels of funding for pediatric research and pressure to close studies with slow accrual limit a center's ability to engage in such research. Addressing funding streams was outside the scope of this project. Finally, the issue of uniform reporting of outcome data to allow patient comparison of HSCT outcomes by transplant center is being handled by the Center for International Blood and Marrow Transplant Research (CIBMTR).16 CIBMTR was awarded a contract to administer the Stem Cell Therapeutic Outcomes Database (SCTOD) of the C.W. Bill Young Cell Transplantation Program. The Key Informants discussed that while this database is not perfect, it provides statistics on outcomes from autologous, related and unrelated allogeneic transplants performed by U.S. transplant centers.

As described above, during teleconference #2 the combined Key Informant panel discussed relevant Key Questions for each gap, and followup calls were conducted with members unable to attend the main call. Consensus on the important Key Questions for each gap was achieved. Therefore, no additional ranking of Key Questions was performed.

The final prioritized list of research gaps and Key Questions, in order of priority are:

### Research Gap Number 1

Mitigation of long-term adverse effects by changes in regimen, including reduced intensity approaches, and changes in subsequent medical or psychosocial intervention.

Reason for Gap: insufficient information (too few studies in the literature)

### Research Question Number 1.1

Can intense psychological support of patient, parents and siblings prevent development of post-transplant psychological disorders (including PTSD, depression, anxiety, other adverse psychological outcomes) in “surviving” and “nonsurviving” family members?

- Population (P) – family members of and pediatric patients undergoing HSCT
- Intervention (I) – intense psychological support
- Comparator (C) – standard psychological support
- Outcomes (O) – incidence of post-transplant psychological disorders among patients and their family members
- Settings (S) – outpatient (may be delivered inpatient while undergoing HSCT)

### Research Gap Number 2

Role of novel therapies for HSCT in altering short-term adverse effects and the long-term effects of these therapies. Such approaches include:

a. novel cellular therapies (such as natural killer-cell therapy), and
b. immunomodulatory therapies (including vaccine therapy).

Reason for Gap: insufficient information (too few studies in the literature)

### Research Question 2.1

For pediatric patients receiving a transplant due to cancer: Are there interventions that may mitigate immediate and late adverse effects without interfering with the immunotherapeutic effects?

- Population (P) – pediatric patients undergoing HSCT for cancer
- Intervention (I) – novel approaches to HSCT such as reduced intensity, cellular and immunomodulatory therapies.
- Comparator (C) – standard approaches to HSCT
- Outcomes (O) – toxicities, antigen-specific immunity, overall survival
- Settings (S) – inpatient

### Research Question 2.2

For pediatric patients receiving a transplant for noncancer indications: Are there interventions that may mitigate immediate and late adverse effects without interfering with the establishment and maintenance of chimerism?

- Population (P) – pediatric patients undergoing HSCT for noncancer indications
- Intervention (I) – novel approaches to HSCT such as reduced intensity, cellular and immunomodulatory therapies.
- Comparator (C) – standard approaches to HSCT
- Outcomes (O) – toxicities, antigen-specific immunity, overall survival
- Settings (S) – inpatient

### Research Gap Number 3

Impact on outcomes of a “family-centered” approach to transplantation. Advocates of children who have undergone HSCT transplantation defined such an approach as including:

a. emotional and psychosocial counseling for the family with a special attention on donor and nondonor siblings,
b. information to share with caregivers and peers, and
c. provision of tools rather than only a large amount of information for navigating the complexities of the medical system and medication management.

Reason for Gap: insufficient information (too few studies in the literature)

### Research Question 3.1

What approaches to integrated care, from diagnosis forward, have the greatest impact in family functioning and overall health and well-being for families faced with pediatric transplant?

- Population (P) – families (parents and siblings) of pediatric patients undergoing HSCT
- Intervention (I) – organized interventions addressing the needs of the families including process, medical, psychosocial, pharmacy.
- Comparator (C) – no organized family intervention
- Outcomes (O) – measures of family functioning, overall health of family members of the transplant patient.
- Settings (S) – outpatient

### Research Gap Number 4

Effectiveness of survivorship planning on long term, comprehensive followup and outcomes.

Reason for Gap: insufficient information (too few studies in the literature)

### Research Question 4.1

Does survivorship planning enhance compliance with long-term followup?

- Population (P) – pediatric patients undergoing HSCT
- Intervention (I) – A comprehensive care summary and followup plan that summarizes treatment and sets forth standards for future care and post-treatment needs.
- Comparator (C) – standard of care
- Outcomes (O) – compliance with long-term followup after HSCT
- Settings (S) – outpatient

### Research Question 4.2

What are the comparative outcomes for those that participate in long-term survivorship followup versus those who do not?

- Population (P) – pediatric patients undergoing HSCT
- Intervention (I) – organized survivorship/long-term care plan
- Comparator (C) – standard of care
- Outcomes (O) – overall survival and incidence rates of late effects
- Settings (S) – in- or outpatient

The specific research projects to address each gap and Key Question are described in more detail in the following section. For the assessment of study designs we evaluated the appropriateness of a randomized trial, a nonrandomized trial, and a prospective cohort. The low number of comparative studies in the field highlights the difficulty in completing research. However, in our analysis of the appropriate study designs, we felt it would be important to restrict our discussions to designs where comparisons could be made. While a retrospective design with a control group can offer comparison and we have used that suggestion below, in general, the research questions focus on new interventions for which there are limited existing data.

### Research Question Number 1.1

Can intense psychological support of patients, parents and siblings prevent development of post-transplant psychological disorders (including PTSD, depression, anxiety, other adverse psychological outcomes) in surviving and nonsurviving family members? (Table 3)

Table 3 Study design evaluations for research question 1.1

Study Design Considerations | Randomized Trial | Nonrandomized Comparative Study | Prospective Cohort
[underlined: Description of design] | Individual participants randomly assigned to intense psychological support or no support for a period following transplant. Centers could be the unit of analysis and randomized to provide intense psychological support or usual care after transplantation. A disadvantage of this over individual patient randomization is that outcomes for patients from a given center are not independent and other aspects of care may help account for differences in outcomes. | Individual participants assigned by nonrandom process to intense psychological support or no support for a period following transplant. Individual centers are assigned to provide intense psychological support or usual care after transplantation. A disadvantage of this over individual patient randomization is that outcomes for patients from a given center are not independent and other aspects of care may help account for differences in outcomes. | Individuals participants at centers offering intense psychological support can elect to receive the support or not. Data are collected on psychological health pretransplant, and continued data collection and monitoring of the development of post-transplant psychological disorders up to a specified time post-transplant.
[underlined: Resource Use, Size and Duration] | Likely to require substantial resources to recruit and treat the patients and their families. The outcome is common so fewer patients are needed to see a difference between groups and patients with varied indications for transplant could be combined in the same study. For studies of centers recruitment of sufficient number of practices willing to be randomized can be a constraint, so sample size considerations may continue to be an issue. | Lower resource use than randomized studies, but will require resources to ensure monitoring of the protocol. Recruitment of sufficient number of centers may still be difficult. | Low resource use compared with alternatives, other than data collection of intent and outcomes. Psychological services in this design will be provided by the centers. Involvement from multiple centers will be necessary to recruit enough patients.
[underlined: Ethical, Legal and Social Issues]: | Ethical issues are minimal as the effectiveness of the intervention in this population is uncertain, and usual care is the comparator. The enrollment/consent process for children in research can be a challenge. | Ethical and legal issues are similar. | No major ethical or legal issues other than the enrollment and consent process for children in research can be a challenge.
[underlined: Availability of data or ability to recruit]: | Recruitment is a challenge as the numbers of patients at any one center is small. Therefore it will require a multicenter study. As the intervention is non-drug randomization may not offer as large a barrier as in a drug trial. However there may be social stigmas associated with psychological services. | Recruitment may face the same challenges although the elimination of randomization may be beneficial as for example their physician may choose the group they enter. However there may be social stigmas associated with psychological services. | No major challenges to recruitment other than the multicenter nature of the study.
[underlined: Advantages of study design for producing a valid result:] | The design is feasible although may take a relatively long time. It should produce the most valid results. | While this design may be more acceptable within the patient community, it will produce less valid results and is therefore less efficient than a randomized design. | Strong potential for confounding, and crossover may occur. The design offers good generalizability, because it replicates a real world environment.

The study design evaluations for research questions 2.1 and 2.2 were combined as they would require the same design and face similar challenges (Table 4).

Table 4 Study design evaluations for research questions 2.1 and 2.2

Study Design Considerations | Randomized Trial | Nonrandomized Comparative Study | Retrospective Cohort
[underlined: Description of design] | Individual participants randomly assigned to receive a novel therapy or standard of care. Patients are followed post-transplant; data collected on toxicities (short-term) and late-effects. | Individual participants assigned by nonrandom process to receive a novel therapy or standard of care. Patients are followed post-transplant; data collected on toxicities (short-term) and late-effects. | Patients who have been treated with novel therapies (exposed) and standard of care (non-exposed) post-transplant.
[underlined: Resource Use, Size and Duration] | Likely to require substantial resources to recruit and follow patients. The short-term effects and late toxicities are a mix of rare and common. However, multicenter studies would be employed to recruit patients in a timely manner due to the small number of patients at any one center. | Lower resource use than randomized studies, but will require resources to ensure monitoring of the protocol. Recruitment of sufficient number of patients may still be difficult. | Using an existing dataset is far less resource intensive than generating new data. But, there may be costs associated with using the data.
[underlined: Ethical, Legal and Social Issues]: | Substantial ethical issues as the effectiveness of the interventions is uncertain. Enrollment/consent process for children in research can be challenging. | Ethical and legal issues are similar but reduced in a scenario where allocation is not randomized. The enrollment and consent process for children in research can be a challenge. | No major ethical or legal issues.
[underlined: Availability of data or ability to recruit]: | Recruitment may be slow and numbers at any one center are small. Therefore it will require a multicenter study. | Recruitment may face the same challenges, although the elimination of randomization may be beneficial for example their physician may choose the group they enter. | No major challenges other than negotiating with those who control the data.
[underlined: Advantages of study design for producing a valid result:] | The design is feasible and would be likely to produce the most valid results, as important characteristics such as indication for treatment should be balanced between the two groups. | Lack of randomization will reduce the validity of the results. While this design may be more acceptable within the patient community, it will produce less-valid results and is therefore less efficient than a randomized design. | Strong potential for confounding, if using a database like CIBMTR where all transplants are to be reported, although there is lower likelihood of biased reporting. Patient selection for novel therapies may be a significant concern. A retrospective design is a good way to generate hypotheses for the design of a focused RCT for novel therapies.

### Research Question 2.1

For pediatric patients receiving a transplant for cancer: Are there interventions that may mitigate immediate and late adverse effects without interfering with the immunotherapeutic effects?

### Research Question 2.2

For pediatric patients receiving a transplant for noncancer indications: Are there interventions that may mitigate immediate and late adverse effects without interfering with the establishment and maintenance of chimerism?

### Research Question 3.1

What approaches to integrated care, from diagnosis forward, have the greatest impact in family functioning and overall health and well-being for families faced with pediatric transplant? (Table 5)

Table 5 Study design evaluations for research question 3.1

Study Design Considerations | Randomized Trial | Nonrandomized Comparative Study | Prospective Cohort
[underlined: Description of design] | Randomize patients and their families to be enrolled in a medical home or receive usual care. Data on measures of family functioning, health of family members and overall family well-being. | Assign patients and their families in a non-random way to be enrolled in a medical home or receive usual care. Data on measures of family functioning, health of family members and overall family well-being. | Families of patients who will undergo HSCT will be enrolled in a cohort; data on all interventions at intake and ongoing psychosocial care that the families received from diagnosis through a pre-defined post-transplant period will be recorded, as well as measures of family functioning, individual health of family members, and overall family well-being.
[underlined: Resource Use, Size and Duration] | The study outcomes are common so fewer families are needed to see a difference between groups and patients with varied indications for transplant could be combined in the same study. Patients would need to be followed for a pre-defined period post-transplant. | Resource use would be similar to randomized trial. | Resources needed are substantial to enroll and follow multiple family members.
[underlined: Ethical, Legal and Social Issues]: | Ethical issues are minimal as the effectiveness of the interventions is uncertain. The enrollment and consent process for children in research can be a challenge. | Ethical and legal issues are similar but reduced in a scenario where allocation is not randomized. The enrollment and consent process for children in research can be a challenge. | No major ethical or legal issues other than the enrollment and consent process for children in research.
[underlined: Availability of data or ability to recruit]: | Recruitment may be slow and numbers at any one center are small. Therefore it will require a multicenter study. | Recruitment may face the same challenges. Although the elimination of randomization may be beneficial as for example their physician may choose the group they enter. | Since a treatment is not being assigned, this design is more acceptable than an RCT. However, multiple family members are asked to engage in a research process to measure very personal issues.
[underlined: Advantages of study design for producing a valid result:] | The design is feasible and would be likely to produce the most valid results, as important characteristics such as indication for treatment should be balanced between the two groups. | Lack of randomization will reduce the validity of the results. While this design may be more acceptable within the patient community, it will produce less valid results and is therefore less efficient than a randomized design. | Strong potential for confounding. However, since the design is prospective, data to account for potential confounding factors can be collected. This work will generate hypotheses for the design of focused RCTs.

### Research Question 4.1

Does survivorship planning enhance compliance with long-term followup? (Table 6)

Table 6 Study design evaluations for research question 4.1

Study Design Considerations | Randomized Trial | Nonrandomized Comparative Study | Retrospective Cohort
[underlined: Description of design] | Individual participants randomly assigned to receive specific survivorship plan or to receive standard instructions for followup. Patients are followed post-transplant; data collected on compliance with followup. | Individual participants assigned in a non–random way to receive specific survivorship plan or to receive standard instructions for followup. Patients are followed post-transplant; data collected on compliance with followup. | Patients who have been treated and received a long-term care or survivorship plan (exposed) and standard of care (nonexposed) are enrolled.
[underlined: Resource Use, Size and Duration] | Likely to require substantial resources to recruit and follow the patients. Due to the rarity of transplant patients would need to be recruited from multiple centers. | Lower resource use than randomized studies, but will require resources to ensure monitoring of the protocol. Recruitment of sufficient number of patients may require multiple centers. | Using an existing dataset is far less resource intensive than generating new data. But, there may be costs associated with using the data. And, a dataset that includes information survivorship planning may not exist.
[underlined: Ethical, Legal and Social Issues]: | Ethical issues are moderate as the effectiveness of the intervention is uncertain, but the perception may be that important family care is being withheld from the control group. The enrollment and consent process for children in research can be a challenge. | Ethical and legal issues are similar but reduced in a scenario where allocation is not randomized. The enrollment and consent process for children in research can be a challenge. | No major ethical or legal issues.
[underlined: Availability of data or ability to recruit]: | Recruitment may be slow and numbers at any one center are small. Therefore it will require a multi-center study, and families may not want to be randomized as they perceive the medical home model to be beneficial. | Recruitment may face the same challenges although the elimination of randomization may be beneficial as for example their physician may choose the group they enter. | No major challenges other than negotiating with those who control the data, if available.
[underlined: Advantages of study design for producing a valid result:] | The design would be likely to produce the most valid results as important characteristics, such as indication for treatment, should be balanced between the two groups. However, it may not be feasible to recruit adequate numbers of families. | Lack of randomization will reduce the validity of the results. While it may be more acceptable within the patient community it will produce less valid results and is therefore less efficient than a randomized design. | Strong potential for confounding, if using a database like CIBMTR where all transplants are to be reported, but there is lower likelihood of biased reporting. Accounting for patient grouping by center will be important in the analysis as survivorship planning is likely to be offered to all patients at one center or not. While the results may be less valid than for an RCT, this may be a more feasible way to approach the question.

### Research Question 4.2

What are the comparative outcomes for those that participate in long-term survivorship followup versus those who do not? (Table 7)

Table 7 Study design evaluations for research question 4.2

Study Design Considerations | Randomized Trial | Nonrandomized Comparative Study | Retrospective Case-Control | Retrospective Cohort
[underlined: Description of design] | Within centers not offering survivorship planning, Individual patients randomly assigned to receive specific survivorship plan or to receive standard instructions for followup. Patients are followed post-transplant; data collected on overall survival, incidence of late-effects and quality of life. | Individual patients are assigned (based on current practice of their center) to have survivorship care planning or not. Patients are followed post-transplant; data collected on overall survival, incidence of late-effects and quality of life. | Patients who have been treated and developed late effects (cases) or did not develop late effects (non-case) are included. Data are collected retrospectively on whether survivorship planning was provided to the patients post-transplant. | Patients who have been treated and received a long-term care or survivorship plan (exposed) and standard of care (non-exposed) are included.
[underlined: Resource Use, Size and Duration] | Likely to require substantial resources to recruit and follow the patients. Patients will need to be followed for at least 5 years for enough events to occur to enable a comparison and to measure quality of life after immediate post-transplant effects and regimen have ended. | Lower resource use than randomized studies, but will require resources to ensure monitoring of the protocol. Patients will need to be followed for at least 5 years for enough events to occur to enable a comparison and to measure quality of life after immediate post-transplant effects and regimen have ended. | Using an existing dataset is far less resource intensive than generating new data. But, there may be costs associated with using the data. And, a dataset that includes information on survivorship planning may not exist. Also, may not be enough cases who had survivorship planning to measure the impact. | Using an existing dataset is far less resource intensive than generating new data. But, there may be costs associated with using the data. And, a dataset that includes information on whether survivorship planning was executed may not exist.
[underlined: Ethical, Legal and Social Issues]: | Ethical issues are minimal as the effectiveness of the intervention is uncertain. The enrollment and consent process for children in research can be a challenge, but in this case as no treatment is given, it should be easier. | Ethical and legal issues are similar but reduced in a scenario where allocation is not randomized. The enrollment and consent process for children in research can be a challenge, but in this case as no treatment is given, it should be easier. | No major ethical or legal issues. | No major ethical or legal issues.
[underlined: Availability of data or ability to recruit]: | Recruitment may be slow and numbers at any one center are small; therefore, it will require a multicenter study. Randomization may present a barrier if survivorship planning is perceived as a beneficial service by the patient and their family. | Recruitment may face the same challenges, although the elimination of randomization may be beneficial. | No major challenges other than negotiating with those who control the data. | No major challenges other than negotiating with those who control the data.
[underlined: Advantages of study design for producing a valid result:] | The design would be likely to produce the most valid results, as important characteristics such as indication for treatment should be balanced between the two groups. | Lack of randomization will reduce the validity of the results. While it may be more acceptable within the patient community, it will produce less valid results and is therefore less efficient than a randomized design. In addition, the elimination of randomization will not overcome the limited number of patients available for analysis. | Strong potential for confounding, if using a database like CIBMTR where all transplants are to be reported, but there is lower likelihood of biased reporting. Controlling for the center will be important in the analysis as survivorship planning is likely to be offered to all patients at one center or not. While the results may be less valid than if an RCT were used, this may be a more feasible way to approach the question. | Strong potential for confounding, if using a database like CIBMTR where all transplants are to be reported, but there is lower likelihood of biased reporting. Controlling for the center will be important in the analysis as survivorship planning is likely to be offered to all patients at one center or not. While the results may be less valid than if an RCT were used, this may be a more feasible way to approach the question.