# References

1 Ratko TA, Belinson SE, Brown HM, et al. Comparative Effectiveness of Hematopoietic Stem-Cell Transplantation in the Pediatric Population. Rockville, MD. Agency for Healthcare Research and Quality. 2011. (In press).
2 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
3 Mauger Rothenberg B, Marbella A, Belinson SE, et al. Future Research Needs for Comparative Effectiveness of Treatments for Localized Prostate Cancer. Future Research Needs Paper No. 4 (Prepared by Blue Cross and Blue Shield Association, Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I) AHRQ Publication No. 10-EHC072-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2010. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
4 Robinson K Saldanha IJ Mckoy NA Frameworks for determining research gaps during systematic review.Manuscript in draft format
5 Advantages and disadvantages of different study designs for future research needs. AHRQ Manuscript in draft form.
6 Copelan EA. Hematopoietic stem-cell transplantation. N Engl J Med. Apr. 27. 2006;354(17):1813-26. [pmid: 16641398].
7 Mosher CE, Redd WH, Rini CM, et al. Physical, psychological, and social sequelae following hematopoietic stem cell transplantation: a review of the literature. Psychooncology. Feb. 2009;18(2):113-27. [pmid: 18677717].
8 Smith MY, Redd W, DuHamel K, et al. Validation of the PTSD Checklist-Civilian Version in survivors of bone marrow transplantation. J Trauma Stress. Jul. 1999;12(3):485-99. [pmid: 10467557].
9 Frequency and correlated of PTSD after bone marrow transplant. 20th Annual Meeting of the Society of Behaviorial Medicine. 1999. San Diego, CA.
10 Young GS, Mintzer LL, Seacord D, et al. Symptoms of posttraumatic stress disorder in parents of transplant recipients: incidence, severity, and related factors. Pediatrics. Jun. 2003;111(6 Pt 1):e725-31. [pmid: 12777592].
11 DuHamel KN, Mosher CE, Winkel G, et al. Randomized clinical trial of telephone-administered cognitive-behavioral therapy to reduce post-traumatic stress disorder and distress symptoms after hematopoietic stem-cell transplantation. J Clin Oncol. Aug. 10. 2010;28(23):3754-61. [pmid: 20625129].
12 Joint Principles of the Patient-Centered Medical Home. Available at: http://www.aafp.org/pcmh/principles.pdf. July 7, 2011.
13 Pasquini MC, Wang Z. Current use and outcome of hematopoietic stem cell transplantation Summary Slides, 2010. Available at: http://www.cibmtr.org. 2010. July 7, 2011.
14 A National Coalition for Cancer Survivorship and Institute of Medicine National Cancer Policy Forum Workshop, The Lance Armstrong Foundation and The National Cancer Institute. Hewitt Maria, Ganz Patricia A. Rapporteurs. Implementing Cancer Survivorship Care Planning. The National Academies Press. 2007.
15 Pediatric Blood and Marrow Transplant Consortium (PBMTC). PBMTC website. Available at: http://www.pbmtc.org/default.aspx. July 7, 2011.
16 Center for International Blood and Marrow Transplant Research (CIBMTR). CIBMTR website. Available at: http://www.cibmtr.org/ReferenceCenter/SlidesReports/USStats/pages/index.aspx. July 7, 2011.