# Methods

Figure 4 outlines the process steps of this future research project on HSCT for pediatrics. The details are described in the text.

Figure 4 Outline of the process steps of the future research needs project on HSCT in pediatrics

Abbreviations: ASBMT = American Society of Blood and Marrow Transplantation; BCBSA EPC = Blue Cross and Blue Shield Association Evidence-based Practice Center; CER = Comparative Effectiveness Review; EPC = Evidence-based Practice Center; FRN = Future Research Needs; HSCT = hematopoietic stem-cell transplantation; KI = Key Informant

The figure shows the outline of the process of the report. Preliminary assessment from the EPC of gaps identified in BCBSA TEC CER and ongoing research was shared with a group of key informants, with the feedback being used to refine the list and move to a prioritization exercise. There is a natural continuum of steps: The first step was to develop and approatch to the project, then generate a list of research gaps, based on a discussion with KIs of methodological, epidemiological and clinical considerations, but not on formal quantitative analyses. After identifying gaps, a list of key question to address each gap was generated with discussion and feedback from key informants (included clinical experts, patient advocates and a payer representivive). After key question generation, the list was further refined through KI feedback. Key questions to address research gap were then agreed on through consensus on a teleconference. Feedback from key informants was sought during the duration of the project via teleconference, email or interview.

First, research gaps were identified through the BCBSA TEC draft CER. After the draft report was submitted, the HSCT CER literature search was updated and clinicaltrials.gov was searched to identify any ongoing research studies that might address the evidence gaps. Next, stakeholders were identified and through and iterative process the gaps were shared with and refined by these stakeholders (see section on engagement of stakeholders, researchers and funders). A final group of stakeholders comprised of transplant physicians, one patient advocate and a payer was formed, this group prioritized the refined evidence gaps, and generated Key Questions (see sections on criteria for prioritization, and research question development). Gaps were prioritized through the web using the SurveyMonkey^®^ Web site. Finally, the exploration of various research designs was conduction solely by the EPC. Details of these steps follow.

## Identification of Evidence Gaps

A link to the draft HSCT CER and a full list of all diseases and indications reviewed in the draft report were presented to the original group of key informants before the first meeting. Four of these key informants had previously served as key informants and technical expert panel members on the BCBSA TEC HSCT CER. In addition, the CER literature was updated (see Appendix D for the search strings), but few newly published studies were found, as the BCBSA TEC draft CER had been recently completed. Searches of ClinicalTrials.gov identified any ongoing research studies that might address the evidence gaps (Appendix E).

As described above, the following crosscutting gaps identified in the draft HSCT CER, or subsequent to the draft CER in preparation for the future research needs project were the gaps that the original Key Informants believed to the most relevant to this future research needs report. The following gaps were then presented to additional key informants as is detailed in the engaging stakeholders, researchers and funders section below.

- Can the long-term adverse effects of HSCT be mitigated by changes in HSCT regimen and/or subsequent interventions?
- What are long-term consequences of HSCT (overall survival, functional measures, quality of life, and adverse effects (including infertility and secondary malignancies)?
- What are the opportunities and obstacles for improving multicenter collaboration to increase accrual of patients and systematize reporting of outcomes and/or to improve the ability to aggregate data across sites?
- Can a framework be developed to help decision makers incorporate contextual factors (such as the potential for new research, rarity of the disease, etc.) into the interpretation of the strength of the evidence. However, for the purposes of this review we considered it methodological issue, which would draw on other expertise and is therefore outside the scope of this future research project.

In the draft HSCT CER, the BCBSA TEC EPC discussed the challenges in grading a body of evidence for a rare disease. However, the examination of methodological issues for systematic review was outside the scope of the present future research needs project. The development of a framework requires a focus on a different body of literature and engagement of different Key Informants, both oriented to methods.

## Criteria for Prioritization

In criteria for prioritization, we drew on our experience from a future research project titled Future Research Needs for Localized Prostate Cancer,3 in which the Effective Health Care (EHC) Program Selection Criteria (see Appendix F) were modified to be applicable to primary research rather than to systematic reviews of original research.4 They keep the spirit of the EHC criteria but are more succinct and accessible to the Key Informants (Table 2). The criteria were used to prioritize gaps and Key Questions, and, when necessary, proposed studies. Appropriateness and importance were the main criteria for prioritizing Key Questions, while desirability, feasibility, and potential impact played a larger role when prioritizing the proposed research studies. The modified EHC Program Selection Criteria were distributed to Key Informant panel members each time they were asked to prioritize gaps or Key Questions. Prioritization of study designs was handled by the EPC in accordance with the AHRQ funded methods work under development.5

Table 2 Prioritization criteria for research gaps and proposed research studies

Category | Criterion
Current importance | ▪ Incorporates both clinical benefits and harms.
Current importance | ▪ Represents important variation in clinical care due to controversy/uncertainty regarding appropriate care.
Current importance | ▪ Addresses high costs to consumers, patients, health care systems, or payers.
Current importance | ▪ Utility of available evidence limited by changes in practice, e.g., disease detection.
Potential for significant health impact | ▪ Potential for significant health impact:; ○ To improve [underlined: health outcomes].; ○ To reduce [underlined: significant variation] related to quality of care.; ○ To reduce [underlined: unnecessary burden] on those with health-care problems.
Potential for significant health impact | ▪ Potential for significant economic impact, reducing unnecessary or excessive costs.
Potential for significant health impact | ▪ Potential for evidence-based change.
Potential for significant health impact | ▪ Potential risk from inaction, i.e., lack of evidence for decisionmaking produces unintended harms.
Potential for significant health impact | ▪ Addresses inequities, vulnerable populations, patient subgroups with differential impact (e.g., by age).
Incremental value | - Adds useful new information to existing portfolio of research on topic OR
Incremental value | - Validates existing research when body of evidence is scant.
Feasibility | Factors to be considered:
Feasibility | ▪ Interest among researchers.
Feasibility | ▪ Duration.
Feasibility | ▪ Cost.
Feasibility | ▪ Methodological complexity (e.g., do existing methods need to be refined?).
Feasibility | ▪ Implementation difficulty.
Feasibility | ▪ Facilitating factors.
Feasibility | ▪ Potential funders.

As a group of clinical experts in HSCT in pediatrics, the original Key Informant panel provided insight into how future research agendas and proposed studies to address gaps fit within these prespecified criteria.

## Methods for Ranking Research Gaps

Research Gaps were ranked via the SurveyMonkey^®^ Web site. Key informants were sent a link to the Web site where they ranked the research gaps from 1 to 7 and generated Key Questions for each gap (Appendix G). The survey allowed each rank to be used only once. Points were assigned to each gap: 1 point for a ranking of seventh, up to 7 points for a ranking of first. The gap with the largest number of points was assigned the highest priority. The comments received from the combined Key Informant panel were reviewed by EPC staff and incorporated where necessary. In addition to the modified EHC Program Selection Criteria, special attention was paid to where Research Gaps overlapped with existing research.

## Engagement of Stakeholders, Researchers, Funders

Central to the methodology of this report was the use of key informants to identify and prioritize evidence gaps. We elicited expert opinion from a group of nine clinical experts (original Key Informant group) with the goal of improving evidence in the area of pediatric HSCT. This original group of Key Informants was comprised of transplant physicians and they were selected to cover the clinical areas in the draft HSCT CER, as well as additional areas important for prioritizing research needs and studies such as ethics and issues of survivorship. Due to the number of disease and disease indications in the CER, this initial group was convened to discuss the best approach for this future research needs project. In recruiting the original Key Informant panel, we contacted Technical Expert Panel (TEP) members from the draft HSCT CER as well as additional clinical experts. This first meeting occurred at the American Society of Blood and Marrow Transplantation (ASBMT) meeting in February, 2011.

For this first meeting and to orient the original Key Informants to the project, they received a link to the BCBSA TEC draft HSCT CER; a list of all diseases addressed in the draft CER matched to its draft CER result; and a list of all new literature and ongoing studies, identified by the disease the study was addressing. Additionally, they received a copy of the modified EHC Program Selection Criteria for background (see Table 2). During the initial face-to-face meeting, the original Key Informants were asked to review and discuss the draft CER, its evidence gaps, and potential approaches for the future research project.

To include a broader array of stakeholder input the original Key Informant panel was supplemented with a group of patient advocates and a payer representative. The advocates were identified through advocacy groups and with the help of one of the original Key Informants. The payer was a representative from a Blue Cross and Blue Shield Plan. The patient advocate group contributed to the evidence gap generation through a separate teleconference (advocate call). The patient advocates were oriented to the project through a discussion of the draft CER and the purpose of the future research needs project. The payer was also engaged in a separate one on one call. We solicited input from a broad array of stakeholders to identify gaps, but then to be in compliance with the Paperwork Reduction Act, the final group that prioritized the gaps, and generated and prioritized Key Questions within gap was a combined panel comprised of seven original key informants, one of the patient advocates and the payer.

The list of evidence gaps was circulated to the combined Key Informant panel for discussion, prioritization and preliminary Key Question development. The combined panel was sent a link to the SurveyMonkey^®^ Web site, where they ranked the gaps from 1 to 7 and generated Key Questions for each gap (Appendix G). The comments received from the combined Key Informant panel were reviewed by EPC staff and incorporated where necessary.

A consensus on the important Key Questions for each gap was reached on the combined Key Informant panel teleconference (#2), and confirmed through the two followup calls with the patient advocate and payer who were unable to join the call due to schedule conflicts. Based on this, the EPC staff in consultation with the AHRQ Task Order Officer decided that it would be most appropriate to ask the combined Key Informant panel to approve or disapprove the meeting minutes, but that we would not share a list of the resulting Key Questions. Summaries from the followup interviews were included with the summary comments from the teleconference (#2). These minutes were sent to the combined Key Informant panel for approval or disapproval. Panel members who disapproved were asked to cite their concerns. The comments received from the combined Key Informant panel were reviewed by EPC staff and incorporated where necessary.

To enhance public engagement, AHRQ will solicit broader input on this document by making it available for public input, which may be incorporated and reflected in the final report.

## Research Question Development and Study Design Considerations

A teleconference with patient advocates (advocate call) was used to elicit their comments on the outcomes they feel are important for patients and families from diagnosis forward. These comments were shared with the combined KI panel for consideration during the Key Question generation phase. Key Questions for each evidence gap were generated through Survey Monkey^®^ by the combined KI panel. The list of Key Questions was circulated and discussed on the combined KI teleconference (#2). EPC staff compiled a final list taking the KI comments into consideration.

As described above, the EPC staff evaluated potential study designs to address each of the Key Questions. This approach is consistent with the guidance under development by AHRQ. The appropriateness of any one study design to address an evidence gap was evaluated using the following criteria:

- Advantages of the study design for producing a valid result;
- Resource use, size, and duration;
- Ethical, legal, and social issues;
- Availability of data or ability to recruit

The EPC staff relied on this framework as a guide during discussions of the least biased study design that was likely to be feasible and affordable. Public comments received after the document is posted will be incorporated into the final report.