# Key Informants

The following individuals served as members of the Key Informant Panels described in this report. Their contributions were invaluable. They have not reviewed this report and will not be given the opportunity to do so until it is released publicly by AHRQ.

K. Scott Baker, M.D., M.S.

Fred Hutchinson Cancer Research Center

Seattle, WA

Mitchell S. Cairo, M.D.

New York Medical College

Valhalla, NY

Morton J. Cowan, M.D.

University of California San Francisco

San Francisco, CA

Melanie Goldish, M.A.

Supersibs

Palatine, IL

Henrietta D. Hyatt-Knorr, M.A.

National Institutes of Health

U.S. Department of Health and Human Services

Bethesda, MD

Paul Orchard, M.D.

University of Minnesota Medical School

Minneapolis, MN

Michael Pulsipher, M.D.

University of Utah

Salt Lake City, UT

Alan Rosenberg, M.D.

Wellpoint

Chicago, IL

Miriam Schechter

Patient Advocate

Brooklyn, NY

Monica Tenhoff

Patient Advocate

Cokato, MN

Ann Woolfrey, M.D.

Fred Hutchinson Cancer Research Center

Seattle, WA