# Executive Summary

## Background

For many pediatric indications, the use of hematopoietic stem-cell transplantation (HSCT) is not supported by high-quality trial data. In the absence of these data, the comparative effectiveness and harms of HSCT for these indications is uncertain. The Blue Cross and Blue Shield Association Technology Evaluation Center (BCBSA TEC) Evidence-based Practice Center (EPC) submitted a draft Comparative Effectiveness Review (CER) on HSCT in the pediatric population to the Agency for Healthcare Research and Quality. The six Key Questions addressed by the review evaluated the comparative effectiveness and/or harms of HSCT and alternative therapies for pediatric patients with (1) malignant solid tumors, (2) inherited metabolic diseases, and (3) autoimmune diseases.

Overall there was a low to moderate strength of evidence for the various diseases and outcomes considered. Evidence consisted largely of case series and case reports. There was a preponderance of small uncontrolled studies, as is often the case in the study of rare diseases. Data synthesis was qualitative. Pooling was not attempted, as the data were not amenable to this approach. An effort was made to identify subgroups based on prognostic factors to see if these subgroups showed patterns of treatment success or failure.

The specific recommendations for future research identified in the draft CER follow.

1. For diseases with adequate patient populations, promote multicenter randomized trials to increase the scientific rigor with which HSCT can be evaluated.
2. Use established registries to standardize the collection of demographic data and data on treatments, and to facilitate the evaluation of comparative harms and benefits of treatments.
3. Recognizing that observational studies, including case series, and case reports will continue to be attractive to investigators, recommendations to improve the usefulness and generalizability of such studies are:
  - Conduct prospective studies with contemporaneous treatments.
  - In both single-arm and comparative studies, use comparable categories for key variables, such as disease, anatomic site, disease stage, and prior treatment.
  - Report survival outcomes consistently, with a clear definition of the survival time—that is, time from diagnosis, time from transplant, or time from recurrence.
  - Consistent harms reporting is essential in facilitating the comparative evaluation of two treatments. Complete reporting of treatment-related mortality, secondary malignancy, serious infections, and veno-occlusive disease should be standard.
  - Make studies comparative when possible.
  - Multivariable regression analyses can be helpful in controlling for potential confounders when sufficient sample sizes can be obtained and should adhere to good modeling practices.
  - Study quality in observational studies should be assessed using guidance developed by Deeks et al.1
4. Develop a framework for assessing strength of evidence that is applicable to rare diseases. This should take into account contextual factors related to disease severity, rate of progression, and prognosis that can be used to evaluate the relative risk-benefit ratio of HSCT in clinical decisionmaking
5. For solid tumors, future studies should focus on single diseases and collect detailed information on prognostic factors that may allow for more refined stratification of high-risk categories, which may highlight the patients likely to benefit from HSCT and allow for less uncertainty in the interpretation of results. Followup should be sufficient to assess the impact of HSCT on the development of secondary malignancies and the long-term impact on neurocognitive development and fertility.
6. For pediatric patients with slowly progressive forms of inherited metabolic diseases, controlled trials with sufficient followup are needed to evaluate the long-term balance of benefit and harms. Trials should use standardized measures of neurocognitive and neurodevelopmental outcomes.
7. For pediatric patients with autoimmune diseases, controlled trials with sufficient followup are needed to evaluate the long-term balance of benefits and harms.

The objective of this Future Research Needs project was to systematically prioritize research gaps in the areas of HSCT for pediatric malignant solid tumors, inherited metabolic diseases, and autoimmune diseases, and to develop a list of research questions to address the prioritized gaps.

In the first stage of this Future Research Needs report, we engaged a group of Key Informants to help develop the approach. (See “Engagement of Stakeholders, Researchers, and Funders” in the full report.) The draft CER that the Key Informants reviewed addressed over 40 diseases, with many diseases having more than one indication for transplant. After reviewing the draft CER, the Key Informants concluded that the Future Research Needs project should be focused on crosscutting evidence gaps that may be pertinent to all or some of these diseases. They stressed that the focus should be on the field as a whole, rather than specific diseases or groups of diseases. Based on these discussions, the crosscutting gaps identified in the draft CER on HSCT in the pediatric population that are pertinent to this project were identified. They are listed below.

One crosscutting evidence gap may be pertinent to all or some of these diseases:

- What are the long-term consequences of HSCT, such as overall survival; functional measures; quality of life; and adverse effects, including infertility and secondary malignancies?

In addition, two crosscutting issues were related to research methods and practice:

- What opportunities and obstacles exist for improving multicenter collaboration, increasing accrual of patients, and systematizing the reporting of outcomes and/or improving the ability to aggregate data collected at individual sites?
- Can a framework be developed to help decisionmakers incorporate contextual factors (the potential for new research, rarity of the disease, etc.) into the interpretation of the strength of the evidence? However, this is a methodological issue, which would require different expertise from that of the technical experts involved and is therefore outside the scope of this Future Research Needs project.

After the completion of the draft CER and in preparation for the Future Research Needs project, a fourth issue emerged:

- Can the long-term adverse effects of HSCT be mitigated by changes in HSCT regimen and/or subsequent interventions? Comparison of specific regimens was outside the scope of the CER due to their evolving nature and difficulties in stratifying small populations by regimen. But it is well recognized that regimens vary in their potential for long-term adverse effects, so this was listed among the research gaps considered by the group.

## Methods

First, research gaps were identified through the BCBSA TEC draft CER. After the draft report was submitted, the HSCT CER literature search was updated and clinicaltrials.gov was searched to identify any ongoing research studies that might address the evidence gaps. Next, stakeholders were identified. To ensure the clinical relevance of this project, we elicited expert opinion from a group of nine clinical experts (the original Key Informant group) on the approach of this Future Research Needs project. In addition to the clinical experts, we engaged a group of patient advocates and a payer. The discussion with the patient advocates focused on their perspectives on outcomes that are important for patients and families from diagnosis forward. We also engaged a payer, anticipating that payer perspectives might also differ from those of transplant physicians. In the final phase, a combined Key Informant group was formed, comprised of seven members from the original Key Informant panel, one member of the patient advocate group, and one payer representative. This combined Key Informant group was tasked with ranking evidence gaps, as well as generating and ranking Key Questions.

The results of the teleconferences with the patient advocates were shared with the combined Key Informant panel for consideration during the Key Question generation phase. Key Questions for each evidence gap were generated online by the combined Key Informant panel using SurveyMonkey^®^, an online survey tool. The list of Key Questions was then circulated and discussed on the combined Key Informant teleconference. EPC staff compiled a final list, taking the Key Informant comments into consideration and paying particular attention to areas where ongoing efforts might overlap with prioritized gaps.

In selecting criteria for prioritization, we drew on our experience from a previous Future Research Needs project, “Future Research Needs for Comparative Effectiveness of Treatment of Localized Prostate Cancer.” In that project, the Effective Health Care Program Selection Criteria were modified to be applicable to primary research rather than to systematic reviews of original research. The criteria “Current Importance” and “Potential for Significant Health Impact” were used to rank both research gaps and Key Questions; “Feasibility” was added for the Key Questions in this report.

After the stakeholders ranked the gaps and Key Questions, the EPC evaluated potential study designs to address each Key Question. The appropriateness of any one study design to address an evidence gap was evaluated using the following criteria:

- Advantages of the study design for producing a valid result
- Resource use, size, and duration
- Ethical, legal, and social issues
- Availability of data or ability to recruit

The EPC staff relied on this framework as a guide to identifying the least biased study design that was likely to be feasible and affordable.

## Results

Seven research gaps were identified through a combination of the draft HSCT CER and conversations with Key Informants (including a patient advocate). These gaps are crosscutting in that they apply to more than one indication for HSCT.

Through an iterative process, the Key Informant panel members identified and prioritized research gaps. They then generated and prioritized a list of potential research questions to address these gaps. For the assessment of study designs, EPC staff evaluated the appropriateness of a randomized trial, a nonrandomized trial, and a cohort design. The low number of comparative studies in the field highlights the difficulty in completing research. In our analysis, we restricted our discussions to designs that would allow comparisons to be made.

The final prioritized list of research gaps and Key Questions, in order of priority, follows.

### Research Gap Number 1

Mitigation of long-term adverse effects by changes in regimen, including reduced-intensity approaches, and changes in subsequent medical or psychosocial intervention.

Reason for Gap: Insufficient information (too few studies in the literature)

### Research Question Number 1.1

Can intense psychological support of patients, parents, and siblings prevent development of post-transplant psychological disorders—including post-traumatic stress disorder (PTSD), depression, anxiety, and other adverse psychological outcomes—in surviving and nonsurviving family members?

- Population (P)—Pediatric patients undergoing HSCT and their family members
- Intervention (I)—Intense psychological support
- Comparator (C)—Standard psychological support
- Outcomes (O)—Incidence of post-transplant psychological disorders among patients and their family members
- Settings (S)—Outpatient (may be delivered inpatient while undergoing HSCT)

### Research Gap Number 2

Role of novel therapies for HSCT in altering short-term adverse effects and long-term effects of these therapies. Such approaches include:

a. Novel cellular therapies (such as natural-killer-cell therapy) and
b. Immunomodulatory therapies (including vaccine therapy).

Reason for Gap: Insufficient information (too few studies in the literature)

### Research Question 2.1

For pediatric patients receiving a transplant due to cancer, are there interventions that may mitigate immediate and late adverse effects without interfering with the immunotherapeutic effects?

- Population (P)—Pediatric patients undergoing HSCT for cancer
- Intervention (I)—Novel approaches to HSCT, such as reduced-intensity, cellular, and immunomodulatory therapies
- Comparator (C) —Standard approaches to HSCT
- Outcomes (O) —Toxicities, antigen-specific immunity, overall survival
- Settings (S)—Inpatient

### Research Question 2.2

For pediatric patients receiving a transplant for noncancer indications, are there interventions that may mitigate short-term and late effects without interfering with the establishment and maintenance of chimerism?

- Population (P)—Pediatric patients undergoing HSCT for noncancer indications
- Intervention (I)—Novel approaches to HSCT, such as reduced-intensity, cellular, and immunomodulatory therapies
- Comparator (C)—Standard approaches to HSCT
- Outcomes (O)—Toxicities, antigen-specific immunity, overall survival
- Settings (S)—Inpatient

### Research Gap Number 3

Impact on outcomes of a “family-centered” approach to transplantation. Advocates of children who have undergone HSCT transplantation defined such an approach as including:

a. Emotional and psychosocial counseling for the family, with special attention to donor and nondonor siblings,
b. Sharing information with caregivers and peers, and
c. Providing families tools for navigating the complexities of the medical system and medication management instead of giving only a large amount of information without guidance.

Reason for Gap: Insufficient information (too few studies in the literature)

### Research Question 3.1

What approaches to integrated care, from diagnosis forward, have the greatest impact on family functioning and the overall health and well-being of families faced with pediatric transplant?

- Population (P)—Families (parents and siblings) of pediatric patients undergoing HSCT
- Intervention (I)—Organized interventions addressing the needs of the families, including process, medical, psychosocial, and pharmacy needs
- Comparator (C)—No organized family intervention
- Outcomes (O)—Measures of family functioning, overall health of family members of the transplant patient
- Settings (S)—Outpatient

### Research Gap Number 4

Effectiveness of survivorship planning on long-term comprehensive followup and outcomes.

Reason for Gap: Insufficient information (too few studies in the literature)

### Research Question 4.1

Does survivorship planning enhance compliance with long-term followup?

- Population (P)—Pediatric patients undergoing HSCT
- Intervention (I)—A comprehensive care summary and followup plan that summarizes treatment and sets forth standards for future care and post-treatment needs
- Comparator (C)—Standard of care
- Outcomes (O)—Compliance with long-term followup after HSCT
- Settings (S)—Outpatient

### Research Question 4.2

What are the comparative outcomes for those who participate in long-term survivorship followup versus those who do not?

- Population (P)—Pediatric patients undergoing HSCT
- Intervention (I)—Organized survivorship/long-term care plan
- Comparator (C)—Standard of care
- Outcomes (O)—Overall survival and incidence rates of late effects
- Settings (S)—Inpatient or outpatient

Within Gap 1, the Key Informants were particularly interested in addressing the impact of post-transplant psychological disorders on pediatric HSCT recipients and families. As many as 41 percent of HSCT survivors may have persistent PTSD symptoms for up to 10 years post-transplant. Further, parents of pediatric transplant recipients also have high levels of PTSD. Addressing this gap would add to the minimal literature specifically addressing the psychosocial needs of pediatric patients and families post-HSCT.

According to the Key Informant panel, Gap 2 concerns the future of transplantation as novel approaches are discovered. They kept the Key Questions broad for the purposes of this report as data are too sparse to focus on one area.

Gap 3 was proposed by the patient advocates and endorsed by the combined panel. As the medical-home model takes shape, families of pediatric HSCT recipients are asking if the model might work for them. With the rising number of affected families, addressing this gap could have a large and beneficial impact on how these children and their families receive care.

Finally, Gap 4 focuses on the specifics of survivorship planning or long-term care planning. Cancer advocacy groups and many cancer centers have taken on the task of helping patients and their families develop and document these plans. At issue is whether the creation of such a formal document affects outcomes. The Institute of Medicine has advocated the implementation of survivorship planning, although they acknowledge that prospective research is needed to confirm or refute the assumption that survivorship planning improves outcomes.

## Discussion

The draft HSCT CER addressed more than 40 diseases. Evidence gaps for these diseases are in part due to the fact that we are dealing with rare diseases and the associated difficulty in attaining appropriate sample sizes. Prioritizing research gaps based on findings for specific diseases is problematic. Given the common treatment and other commonalities among families coping with serious and rare diseases, this effort focused on a number of crosscutting research gaps.

In addition to assembling national experts on pediatric HSCT, the EPC engaged a group of patient advocates to discuss treatment outcomes, as well as a payer representative. With the patient advocates, the EPC intended solely to focus on discussing outcomes. While they did provide insight on important patient outcomes, the advocates also broadened the discussion into other areas. These parents identified challenges in coordinating the followup and care of their children, noting that the comparative effectiveness questions need to go beyond chemotherapy regimen and explore issues such as care coordination and the psychosocial needs of the whole family. These patient advocates provided a valuable unique perspective that resulted in the identification of two additional research gaps and associated research questions.

It should be noted that the Key Informants highlighted research needs that were outside the scope of the original review, such as mitigating harms secondary to treatments, exploration of psychosocial harms for the patients and families, and issues of care coordination. While none of these were within the scope of the CER, the Key Informants agreed about the importance of these issues. Current limitations in the published literature, while not reviewed here, provide a clear opportunity for advancement in the field.

Another notable point, coming from the clinical experts, was the need to understand cancer as a pediatric disease. The clinical experts advocated the separation of research on children's cancer from research on adult cancer, as both the disease and treatment have unique implications for a developing body and mind.

## Conclusions

The following four prioritized evidence gaps and Key Questions were identified.

1. Mitigation of long-term adverse effects by changes in regimen, including reduced-intensity approaches, and changes in subsequent medical or psychosocial intervention.
  1.1 Can intense psychological support of patients, parents, and siblings prevent development of post-transplant psychological disorders—including PTSD, depression, anxiety, other adverse psychological outcomes—in surviving and nonsurviving family members?
2. Role of novel therapies for HSCT in altering short-term adverse effects and long-term effects of these therapies. Such approaches include:
  a. Novel cellular therapies (such as natural-killer-cell therapy) and
  b. Immunomodulatory therapies (including vaccine therapy).
  2.1 For pediatric patients receiving a transplant due to cancer, are there interventions that may mitigate immediate and late adverse effects without interfering with the immunotherapeutic effects?
  2.2 For pediatric patients receiving a transplant for noncancer indications, are there interventions that may mitigate short-term and late adverse effects without interfering with the establishment and maintenance of chimerism?
3. Impact on outcomes of a “family-centered” approach to transplantation. Advocates of children who have undergone HSCT defined such an approach as including:
  a. Emotional and psychosocial counseling for the family, with special attention on donor and nondonor siblings,
  b. Sharing information with caregivers and peers, and
  c. Providing families tools for navigating the complexities of the medical system and medication management instead of giving only a large amount of information without guidance.
  3.1 What approaches to integrated care, from diagnosis forward, have the greatest impact on family functioning and the overall health and well-being of families faced with pediatric transplant?
4. Effectiveness of survivorship planning on long-term comprehensive followup and outcomes.
  4.1 Does survivorship planning enhance compliance with long-term followup?
  4.2 What are the comparative outcomes for those who participate in long-term survivorship followup versus those who do not?

## Reference

1 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].