# Discussion

In the pediatric population, HSCT is used to treat a wide variety of diseases, both malignant and nonmalignant. The success of treating many of the pediatric diseases with HSCT has resulted in an increased number of long-term survivors. The draft HSCT CER addressed over 40 diseases. Evidence gaps for these diseases are in part due to the fact that we are dealing with rare diseases and the associated difficulty attaining appropriate sample sizes. Prioritizing research gaps based on findings for specific diseases is problematic, as the results may appear to favor one disease over another. Given the common treatment and other commonalities among families coping with serious and rare diseases, important, crosscutting research gaps were identified.

Inherent in the scope of the draft HSCT CER were challenges in developing the future research needs report. As noted, crosscutting issues came to the center of the future research needs project. Engaging key informants who could speak to each of the diverse diseases addressed in the draft CER was infeasible. Therefore our outreach to key informants proceeded in several phases. The first focus was on HSCT specialists, then engaging patient advocates, and the health plan perspective. Initiated by the patients but embraced by all key informants were issues of family support and survivorship that were not addressed in the draft CER but were clearly important to incorporate in this follow-on future research needs report. Another inherent challenge was the difficulty of proposing study designs suitable for rare diseases. Not addressed here but of importance to systematic evaluation of evidence is the development of a framework to help decision makers incorporate contextual factors into the interpretation of the strength of evidence.

The discussion among the patient advocates highlighted the importance of appreciating the family unit and the consequences of HSCT for the family as a whole. The patient advocate discussion coalesced around themes central to concept of a patient-centered medical home. They envisioned a care setting that could provide the continuity of support to families through the continuum of disease and survivorship. The continuum includes diagnosis, treatment, transition from treatment center back to the community and long-term followup. For example, the complex pharmacologic regimens patient require, particularly shortly after transplant, require an advanced level of planning and organization from these families.

The patient advocates requested the provision of simple tools to plan medication administration, as well as periodic updates on research on the disease and treatment. The long-term impact of the disease and its treatment should be recognized. Even for children who do well with treatment, routine ongoing monitoring can require upwards of 10 to 15 specialty appointments per year. The time it takes to coordinate these appointments and manage the information flow between the various physicians is challenging, and gaining cooperation from adolescent patients may also be taxing. Thus comparative effectiveness of HSCT needs to be considered in the context of the psychosocial components of the family within the healthcare delivery system.

Another dimension for the family is the impact on siblings. The ability to be or not be a donor may have emotional toll on both the sibling and the patient. Further, if a transplant fails the donor may be faced with additional feelings of responsibility for the continued care of their sibling. Both donor and non-donor siblings of HSCT recipients have their own needs during and post-transplant. Their health is intrinsic to the overall health of the family.

The patient advocates provided a valuable, unique perspective that resulted in the identification of two additional research gaps and associated research questions. Both of these gaps were assigned high priority by the combined clinical, patient, and payer panel; and they are included in the prioritized recommendations.

It should be noted that the key informants highlighted research needs that were outside the scope of the original review such as mitigating harms secondary to treatments, exploration of psychosocial harms for the patients and families and issues of care coordination. While none of these were within the scope of the draft CER there was agreement among the key informants as to the importance of these issues that current limitations in the published literature, while not reviewed here, provide clear opportunity for advancement in the field.

Another notable point, from the clinical experts, was understanding cancer as a pediatric disease. The clinical experts advocated the separation of research on children's cancer from that for adults. Although the diseases may appear to be similar, the implications of both the disease and treatment on a developing body and mind have unique implications.