# Conclusions

This future research project was built from the draft HSCT CER. We used key informants to identify and prioritize evidence gaps. Due to the complexity and the large number of diseases in the draft HSCT CER we focused on crosscutting evidence gaps and Key Questions. The results of this process are the following four prioritized evidence gaps and Key Question:

Research Gap Number 1
- Mitigation of long-term adverse effects by changes in regimen, including reduced intensity approaches, and changes in subsequent medical or psychosocial intervention.

Research Question Number 1.1
- Can intense psychological support of patient, parents and siblings prevent development of post-transplant psychological disorders (including PTSD, depression, anxiety, other adverse psychological outcomes) in surviving and nonsurviving family members?

Research Gap Number 2
- Role of novel therapies for HSCT in altering short-term adverse effects and the long-term effects of these therapies. Such approaches include:
  a. novel cellular therapies (such as natural-killer-cell therapy), and
  b. immunomodulatory therapies (including vaccine therapy).

Research Question 2.1
- For pediatric patients receiving a transplant due to cancer: Are there interventions that may mitigate immediate and late adverse effects without interfering with the immunotherapeutic effects?

Research Question 2.2
- For pediatric patients receiving a transplant for noncancer indications: Are there interventions that may mitigate immediate and late adverse effects without interfering with the establishment and maintenance of chimerism?

Research Gap Number 3
- Impact on outcomes of a “family-centered” approach to transplantation. Advocates of children who have undergone HSCT defined such an approach as including:
  a. emotional and psychosocial counseling for the family with a special attention on donor and non-donor siblings,
  b. information to share with caregivers and peers, and
  c. provision of tools rather than only a large amount of information for navigating the complexities of the medical system and medication management.

Research Question 3.1
- What approaches to integrated care, from diagnosis forward, have the greatest impact in family functioning and overall health and well-being for families faced with pediatric transplant?

Research Gap Number 4
- Effectiveness of survivorship planning on long term, comprehensive followup and outcomes.

Research Question 4.1
- Does survivorship planning enhance compliance with long-term followup?

Research Question 4.2
- What are the comparative outcomes for those that participate in long-term survivorship followup versus those who do not?