# Background

## Clinical Context

For many pediatric indications, the use of hematopoietic stem-cell transplantation (HSCT) is not supported by high-quality trial data. In the absence of these data the comparative effectiveness and harms of HSCT for these indications is uncertain. In February 2011, the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (BCBSA TEC EPC) submitted a draft comparative effectiveness review (CER) on HSCT in the pediatric population to the Agency for Healthcare Research and Quality (AHRQ).1 The aims of the review were to evaluate the comparative effectiveness of HSCT versus conventional therapy for the treatment of malignant solid tumors, inherited metabolic diseases, and autoimmune diseases and to assess the comparative harms.

The success of treating some of the hematopoietic pediatric diseases with HSCT has resulted in an increased number of long-term survivors. As improvements in survival have been achieved, there is greater concern with long-term effects, and how adverse effects (i.e., graft-versus-host disease, opportunistic infections, infertility, and secondary malignancies) might be mitigated. The HSCT CER is a broad-based report for all indications where HSCT is applied. The population was pediatric patients, and the indications for transplant varied by disease.

The six Key Questions addressed by the review evaluated the comparative effectiveness or harms of HSCT and alternative therapies for pediatric patients with (1) malignant solid tumors, (2) inherited metabolic diseases, or (3) autoimmune diseases. See Appendix A for the full Key Questions.

Table 1 displays the conclusions for each indication in the draft HSCT CER by the quality of the evidence as determined by the EPC Program-modified GRADE criteria. Definitions of the quality grades low, moderate or high refer to the level of confidence that the body of evidence reflects the true effect. See Appendix B for a list of conclusions by Key Question and disease and Appendix C for diseases where evidence was insufficient to reach a conclusion. These items were presented to stakeholders in preparation of this report. It should be noted that this future research needs project was based on the draft CER, and based on updated literature searches and peer review comments, the conclusions in the final CER could change.

Table 1 Conclusions for each indication in the BCBSA TEC Draft HSCT CER: Single HSCT versus conventional therapy for overall survival

| Low | Moderate | High
Evidence suggesting comparative benefit of HSCT over conventional therapy | - Relapsed/refractory Astrocytoma; - Attenuated MPS II (Hunter's disease)^*^ | | - Wolman's disease; - Farber's disease Type 2/3^**^
Evidence suggesting no comparative benefit of HSCT over conventional therapy | - Ewing sarcoma family of tumors; - Wilms Tumor; - Newly Diagnosed Glioblastoma Multiforme; - Niemann-Pick Type A^*^; - Niemann-Pick type C^*^; - MPS III (Sanfilippo)^*^; - Farber's disease type I; - Juvenile form of GM1^*^; - Juvenile Tay-Sachs^*^ | - Metastatic Rhabdomyosarcoma Extraocular Retinoblastoma with CNS involvement; - Gaucher Type III^*^; - Severe and attenuated MPS II (Hunters disease)^*^; - Infantile ceroid lipofuscinosis^*^
Evidence suggesting comparative harm of HSCT over conventional therapy | - Nonanaplastic Mixed or Unspecified Ependymoma

Abbreviations: BCBSA TEC = Blue Cross and Blue Shield Association Technology Evaluation Center; CER = Comparative Effectiveness Review; CNS = central nervous system; GM1 = monosialotetrahexosylganglioside; HSCT = hematopoietic stem-cell transplantation; MPS = mucopolysaccharoidosis

* Neurocognitive and neurodevelopmental outcome

** Joint mobility outcome

Evidence consisted largely of case series and case reports. There was a preponderance of small, uncontrolled studies, as is often the case in the study of rare diseases. Data synthesis was qualitative. Pooling was not attempted, as the data were not amenable to this approach. An effort was made to identify subgroups based on prognostic factors to see if these subgroups showed patterns of treatment success or failure.

The objective of this future research needs project is to systematically prioritize research gaps in the areas of HSCT for pediatric malignant solid tumors, inherited metabolic disease, and autoimmune disease and to develop a list of research questions to address the prioritized gaps.

## Evidence Gaps

The draft HSCT CER addressed more than 40 diseases, with many diseases having more than one indication for transplant. These diseases, or the specific indication within these diseases, all are rare. The draft HSCT CER, and thus this future research project, were unusual, in that typically the focus is on one disease with multiple interventions. Here, we focused on one intervention and multiple diseases and disease indications, presenting a challenge for how future research needs are formulated.

The evidence gaps identified in the draft HSCT CER are listed below:

1. For diseases with adequate patient populations, promote multicenter randomized trials to increase the scientific rigor in which HSCT can be evaluated.
2. Use established registries to standardize the collection of demographic data, treatments, and to facilitate the evaluation of comparative harms and benefits of treatments.
3. Recognizing that observational studies, including case series, and case reports will continue to be attractive to investigators, recommendations to improve the usefulness and generalizability of such studies are:
4. Conduct prospective studies with contemporaneous treatments.
  - Patients in both single arm and comparative studies would be comparable in terms of key variables, such as disease, anatomic site, disease stage, and prior treatment.
  - Consistent reporting of survival outcomes, with a clear definition of the survival time, i.e., time from diagnosis, time from transplant or time from recurrence.
  - Consistent harms reporting is essential in facilitating the comparative evaluation two treatments. Complete reporting of treatment related mortality, secondary malignancy, serious infections, and veno-occlusive disease would be standard.
  - Make studies comparative when possible.
  - Multivariable regression analyses can be helpful in controlling for potential confounders, when sufficient sample sizes can be obtained, and would adhere to good modeling practices.
  - Guidance for study quality in observational studies has been addressed by Deeks et al.2
5. Develop a framework for assessing strength of evidence that is applicable to rare diseases. This would take into account contextual factors related to disease severity, rate of progression, and prognosis that can be used to evaluate the relative risk-benefit ratio of HSCT in clinical decisionmaking.
6. For solid tumors, future studies would focus on single diseases, and collect detailed information on prognostic factors that may allow for more refined stratification of high-risk categories which may highlight those likely to benefit from HSCT and allowing for less uncertainty in the interpretation of results. Followup would be sufficient to assess the impact of HSCT on the development of secondary malignancies and long-term impact on neurocognitive development and fertility.
7. For pediatric patients with slowly progressive forms of inherited metabolic diseases, controlled trials with sufficient followup are needed to evaluate the long-term balance of benefit and harms. Trials would use standardized measure of neurocognitive and neurodevelopmental outcomes.
8. For pediatric patients with autoimmune diseases, controlled trials with sufficient followup are needed to evaluate the long-term balance of benefit and harms.

As is detailed in the Methods section, in the first stage of this future research needs report, we engaged a group of key informants to help develop the approach (see section on “Engaging stakeholders, researchers and funders”). In consultation with the key informants, after having reviewed the draft CER they concluded that for this CER which addressed over 40 diseases, with many diseases having more than one indication for transplant, the future research needs project should be focused on crosscutting evidence gaps that may be pertinent to all or some of these diseases. They stressed that the focus should be on the field as a whole, rather than specific diseases or groups of diseases.

Due to these circumstances, the future research needs project focused on crosscutting evidence gaps that may be pertinent to all or some of these diseases. The crosscutting gaps identified in the draft HSCT CER are listed below:

One crosscutting evidence gap may be pertinent to all or some of these diseases.

- What are long-term consequences of HSCT, such as overall survival; functional measures; quality of life; and adverse effects, including infertility and secondary malignancies?

In addition, there are two crosscutting issues related to research methods and practice.

- What are the opportunities and obstacles for improving multicenter collaboration, to increase accrual of patients and systematize reporting of outcomes and/or to improve the ability to aggregate data collected at individual sites?
- Can a framework be developed to help decision makers incorporate contextual factors (such as the potential for new research, rarity of the disease, etc.) into the interpretation of the strength of the evidence? However, for the purposes of this review, we considered it methodological issue, which would draw on other expertise and is therefore outside the scope of this future research project.

In addition, subsequent to the completion of the draft CER, and in preparation for the future research needs project a fourth issue emerged: Can the long-term adverse effects of HSCT be mitigated by changes in HSCT regimen and/or subsequent interventions? Comparison of specific regimens was outside the scope of the CER due to their evolving nature of and difficulties of stratifying small populations by regimen. But, it is well recognized that regimens vary in their potential for long-term adverse effects. Experts involved in the CER considered this issue and agreed that an examination of regimens should remain outside the scope.

### Analytic Framework

Analytic frameworks are shown in Figures 1, 2, and 3.

Figure 1 Analytic framework for HSCT for pediatric malignant solid tumors

The figure shows an analytic framework, i.e., a graph that depicts the key questions of the BCBSA TEC CER and where the major gaps lie. Briefly, patients with pediatric malignant solid tumor can be treated with HSCT or other therapies. The short term effectiveness and safety of the interventions is measured by intermediate outcomes (recurrence free survival and progression free survival) and adverse event data. The long term effectiveness and safety of the interventions is measured overall survival, long term consequences of HSCT, and quality of life. The figure also depicts the major evidence gaps identified in the BCBSA TEC CER. Briefly, the gaps include: lack of long-term outcome data; and methodological issues on the collection of data.

Figure 2 Analytic framework for HSCT for pediatric inherited metabolic diseases

The figure shows an analytic framework, i.e., a graph that depicts the key questions of the BCBSA TEC CER and where the major gaps lie. Briefly, patients with pediatric inherited metabolic diseases can be treated with HSCT or other therapies. The short term effectiveness and safety of the interventions is measured by intermediate outcomes (stable source of endogenous enzyme, stabilization or slowed progression of neurocognitive decline) and adverse event data. The long term effectiveness and safety of the interventions is measured overall survival, cure, long term consequences of HSCT, and quality of life. The figure also depicts the major evidence gaps identified in the BCBSA TEC CER. Briefly, the gaps include: lack of long-term outcome data; and methodological issues on the collection of data.

Figure 3 Analytic framework for HSCT for pediatric autoimmune diseases

The figure shows an analytic framework, i.e., a graph that depicts the key questions of the BCBSA TEC CER and where the major gaps lie. Briefly, patients with pediatric autoimmune diseases can be treated with HSCT or other therapies. The short term effectiveness and safety of the interventions is measured by intermediate outcomes (slowed progression or improvement in organ damage secondary to the autoimmune disease) and adverse event data. The long term effectiveness and safety of the interventions is measured by remission, overall survival, cure, long term consequences of HSCT, and quality of life. The figure also depicts the major evidence gaps identified in the BCBSA TEC CER. Briefly, the gaps include: lack of long-term outcome data; and methodological issues on the collection of data.