# Appendixes

Appendix A Key Questions From Comparative Effectiveness of HSCT for Pediatrics

Appendix B Conclusions From Draft Comparative Effectiveness Review of HSCT

Appendix C Conclusions for Which There Was Insufficient Evidence

Appendix D Search Strategy for Recently Published and Ongoing Studies

Appendix E Ongoing Studies

Appendix F Effective Health Care Program Selection Criteria

Appendix G Tool Used To Solicit KI Research Gap Ratings and Key Questions Via SurveyMonkey^®^ (June 16, 2011)

Appendix H Research Gap Rankings