# Effective Health Care Program Selection Criteria

Appropriateness
- Represents a health care drug, intervention, device, technology or health care system/setting available (or soon to be available) in the U.S.
- Relevant to 1013 enrollees (Medicare, Medicaid, S-CHIP, other federal health care programs
- Represents one of the priority conditions designated by the Department of Health and Human Services

Importance
- Represents a significant disease burden, large proportion or priority population
- Is of high public interest; affects health care decision-making, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular
- Was nominated/strongly supported by one or more stakeholder groups
- Represent important uncertainty for decision-makers
- Incorporates issues around both clinical benefits and potential clinical harms
- Represents important variation in clinical care, or controversy in what constitutes appropriate clinical care
- Represent high costs due to common use, to high unit costs, or to high associated costs to consumers, to patients, to health care systems, or to payers

Desirability of new research/duplication
- Would not be redundant (the proposed topic is not already covered by available or soon-to-be available high-quality systematic review by AHRQ or others)

Feasibility
- Effectively uses existing research and knowledge by considering adequacy of research for conducting a systematic review, and newly available evidence

Potential Impact
- Potential for significant health impact, significant economic impact, potential change, potential risk from inaction, addressing inequities and vulnerable populations, and/or addressing a topic with clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups.