# Ongoing Studies

Appendix Table E1 List of ongoing studies