# Search Strategy for Recently Published and Ongoing Studies

The search strategy was the same one as was used in the BCBSA TEC HSCT CER with dates starting 10/09/09 through January 2011.

All Child: 0-18 years=3709
#107 Search #104 AND #106
#106 Search “Humans”[Mesh]
#104 Search #102 AND #103
#103 Search #55 OR #88 OR #90 OR #101
#102 Search #45 OR #47
#101 Search “Fabry Disease” OR “Fabry's disease” OR “Farber Lipogranulomatosis” OR “Fabry Disease” OR “Fabry's disease” OR “Farber Lipogranulomatosis” OR Gangliosidos* OR “Sandhoff Disease” OR “sandhoff's disease” OR “Gaucher Disease” OR “gaucher's disease” OR “Niemann-Pick Disease*” OR “Tay-Sachs Disease” OR Aspartylglucosaminuria OR “beta-Mannosidosis” OR Mucolipidos* OR “Wolman Disease” OR “Ceroid Lipofuscinos*” OR “Ceroid-Lipofuscinos*” OR galactosialidosis OR Cystinosis OR “Sialic Acid Storage Disease” OR “salla disease” OR “peroxisomal storage disorder*” OR adrenomyeloneuropath* OR “immune cytopenia*”
#90 Search “Ewing's Sarcoma” OR “Wilms Tumor” OR Rhabdomyosarcoma* OR Retinoblastoma* OR Medulloblastoma* OR PNET OR “Primitive Neuroectodermal Tumor*” OR Astrocytoma* OR Mucopolysaccharidos* OR Sphingolipidos* OR “Lysosomal Storage Disease*” OR “Glycogen Storage Disease*” OR “Niemann-Pick Disease*” OR Adrenoleukodystrophy OR “Juvenile Rheumatoid Arthritis” OR “Systemic Lupus Erythematosus” OR SLE OR Scleroderma OR “Crohn Disease” OR “Crohn's disease” OR “Autoimmune Disease*”
#88 Search (((((((((“Mucopolysaccharidoses”[Mesh] OR “Sphingolipidoses”[Mesh]) OR “Lysosomal Storage Diseases”[Mesh]) OR “Glycogen Storage Disease”[Mesh]) OR “Niemann-Pick Diseases”[Mesh]) OR “Adrenoleukodystrophy”[Mesh]) OR “Arthritis, Juvenile Rheumatoid”[Mesh]) OR “Lupus Erythematosus, Systemic”[Mesh]) OR “Scleroderma, Systemic”[Mesh]) OR “Crohn Disease”[Mesh]) OR “Autoimmune Diseases”[Mesh]
#55 Search (((((“Sarcoma, Ewing's”[Mesh] OR “Wilms Tumor”[Mesh]) OR “Rhabdomyosarcoma”[Mesh]) OR “Retinoblastoma”[Mesh]) OR “Medulloblastoma”[Mesh]) OR “Neuroectodermal Tumors, Primitive”[Mesh]) OR “Astrocytoma”[Mesh]
#47 Search “stem cell*” OR “bone marrow”
#45 Search “Bone Marrow Transplantation”[Mesh] OR (“Hematopoietic Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Stem Cell Transplantation”[Mesh])

Additional searching was done to obtain information on comparators in the following diseases:

Diabetes
#15 Search (#10 AND #13) NOT #5 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#14 Search (#10 AND #13) NOT #5
#13 Search “Immunosuppression”[Mesh] OR immunomodulation OR immunosuppressant OR immunosuppressive OR “immune modulation” OR “immune suppression”
#10 Search “Diabetes Mellitus, Type 1”[Mesh] OR (“type 1” AND (diabetes OR diabetic OR DM)) OR “juvenile diabetes”
#5 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”

Other Autoimmune Diseases
#23 Search (#20 AND #13) NOT #5 AND (severe OR refractory OR “poor prognosis”) Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#22 Search (#20 AND #13) NOT #5 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#21 Search (#20 AND #13) NOT #5
#20 Search ((“Arthritis, Juvenile Rheumatoid”[Mesh] OR “Lupus Erythematosus, Systemic”[Mesh]) OR “Scleroderma, Systemic”[Mesh]) OR “Crohn Disease”[Mesh]
#13 Search “Immunosuppression”[Mesh] OR immunomodulation OR immunosuppressant OR immunosuppressive OR “immune modulation” OR “immune suppression”
#5 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”

Appendix Table D1 List of recently published studies