# Conclusions for Which There Was Insufficient Evidence

Insufficient Evidence. Rhabdomyosarcoma of mixed stages, Congenital alveolar rhabdomyosarcoma, Cranial parameningeal rhabdomyosarcoma with metastasis, Allogeneic transplantation of metastatic rhabdomyosarcoma, Germ cell tumor, Central Nervous System Embryonal Tumors, Newly diagnosed anaplastic astrocytoma, Anaplastic ependymoma, Choroid plexus carcinoma, Recurrent/progressive glioblastoma multiforme, Nonanaplastic mixed or unspecified ependymoma, Ewing sarcoma family of tumors Tandem versus Single, Neuroblastoma Tandem versus Single, Mucolipidosis II (I-cell disease), MPS IV (Morquio syndrome)*, aspartylglucosaminuria*

No Evidence Found. Gauchers disease type 2, cystinosis, infantile free sialic acid disease, Fabry's disease, β-mannosidosis, mucolipidosis III or IV, glycogen storage disease type II (Pompe disease), Salla disease, adrenomyeloneuropathy, galactosialidosis (type unspecified) and Sandhoff disease (type unspecified), infantile GM1 gangliosidosis, infantile Tay-Sachs, juvenile ceroid lipofuscinosis, Type 1 diabetes mellitus, and severe/refractory systemic lupus erythematosus, juvenile idiopathic arthritis, systemic sclerosis, malignant multiple sclerosis, Crohn's disease, myasthenia gravis, overlap syndrome, diffuse cutaneous cutis, evans syndrome, autoimmune hemolytic anemia and autoimmune cytopenia.