# Conclusions From Draft Comparative Effectiveness Review of HSCT

## Malignant Solid Tumors (Key Questions 1 and 2)

Evidence Suggesting Comparative Benefit of HSCT Over Conventional Therapy
- For single HSCT for recurrent/progressive anaplastic astrocytoma. The evidence suggests clinical superiority of HSCT over conventional therapy on overall survival. Results from one historic comparison report 5 year survival of 40 percent for HSCT treated pediatric patients (n=10) compared with 0 percent for those treated with conventional therapy. The strength of the body of evidence is low.

Evidence Suggesting Comparative Harm of HSCT Over Conventional Therapy
- For single HSCT for nonanaplastic mixed or unspecified ependymoma. The evidence suggests a comparative harm of HSCT over conventional therapy on overall survival, due to higher treatment related mortality. The strength of the body of evidence is low.

Evidence Suggesting No Comparative Benefit of HSCT Over Conventional Therapy
- For single HSCT for extraocular retinoblastoma with CNS involvement and for metastatic rhabdomyosarcoma. The evidence suggests no comparative benefit of HSCT over conventional therapy on overall survival. The strength of the body of evidence is moderate.
- For single HSCT for high-risk Ewings sarcoma family of tumors, high-risk relapsed Wilm's tumor, and one type of glial tumor (newly diagnosed glioblastoma multiforme. The evidence suggests no comparative benefit of HSCT over conventional therapy on overall survival. The strength of the body of evidence is low.

Insufficient Evidence
- For tandem HSCT versus single HSCT for high-risk Ewings sarcoma family of tumors, neuroblastoma, central nervous system embryonal tumors, and germ cell tumors. The strength of evidence is insufficient to draw conclusions on overall survival.
- For single HSCT versus conventional therapy for central nervous system embryonal tumors, high-risk rhabdomyosarcoma of mixed stages, congenital alveolar rhabdomyosarcoma, cranial parameningeal rhabdomyosarcoma with metastasis, allogeneic transplantation of metastatic rhabdomyosarcoma, extraocular retinoblastoma with no CNS involvement, trilateral retinoblastoma, and five types of glial tumor (newly diagnosed anaplastic astrocytoma, anaplastic ependymoma and choroid plexus carcinoma and recurrent/progressive glioblastoma multiforme, and nonanaplastic, mixed or unspecified ependymoma. The strength of evidence is insufficient to draw conclusions on overall survival.

## Nonmalignant Diseases: Inherited Metabolic Diseases (Key Questions 3 and 4)

The inherited metabolic diseases were split into three categories for this review. Rapidly progressive disease was defined as progression to death within 10 years; the outcome of interest is overall survival. Slowly progressive disease was defined as progression to death of 10 years or greater; the outcomes of interest are neurocognitive and neurodevelopmental measures. Diseases that have both rapidly and slowly progressive forms of disease where outcomes are overall survival and neurocognitive and neurodevelopmental measures respectively.

### Rapidly Progressive Diseases

Evidence Suggesting Comparative Benefit of HSCT Over Conventional Therapy
- For single HSCT for Wolman's disease. The natural history of this disease death occurs by approximately by 6 months of age. Of five cases reported in the evidence three patients are alive at 4-11 years followup, with normal function and attending school. The strength of the body of evidence is high.

Evidence Suggesting No Comparative Benefit of HSCT Over Conventional Therapy
- For single HSCT for Niemann-Pick Type A. The evidence suggests no benefit of HSCT compared with symptom management or disease natural history. One case has been reported and was alive but with neurocognitive and neurodevelopmental decline at age 2.7 years. The strength of the body of evidence is low.

Insufficient Evidence
- The strength of the body of evidence is insufficient to draw conclusions on the comparative benefit of single HSCT compared with symptom management on overall survival for mucolipidosis II (I-cell disease).

No Evidence Found
- There was no evidence on single HSCT for Gauche disease type 2, cystinosis and infantile free sialic acid disease.

### Slowly Progressive Diseases

Evidence Suggesting Comparative Benefit of HSCT Over Conventional Therapy
- For single HSCT for the attenuated form of MPS II (Hunter's disease). The evidence suggests benefit of HSCT compared with enzyme replacement therapy with respect to neurocognitive and neurodevelopmental measures. Three of five transplanted patients were reported to have stable neurocognitive and neurodevelopmental measures at 2-13 years followup. The strength of the body of evidence is low.

Evidence Suggesting No Comparative Benefit of HSCT Over Conventional Therapy
- For single HSCT for both severe and attenuated MPS II (Hunters disease). The evidence suggests no benefit of HSCT compared with enzyme replacement therapy with respect to neurocognitive and neurodevelopmental outcomes. Neurodevelopmental outcomes appear similar for both HSCT and enzyme replacement therapy for the severe and attenuated forms of MPS II both offering some benefit. For the severe form of the disease neither HSCT nor ERT appear to offer a benefit relative to disease natural history. The strength of the body of evidence is moderate.
- For single HSCT for Gaucher Type III. The evidence suggests no benefit for HSCT compared with enzyme replacement therapy with respect to neurocognitive outcomes. Five of eight transplanted patients and seven of nine ERT patients showed stable neurocognitive scores at 1-10 years followup and 2-5 years followup, respectively. The strength of the body of evidence is moderate.
- For single HSCT for Niemann-Pick type C, MPS III (Sanfilippo). The evidence suggests no benefit for HSCT compared with symptom management, substrate reduction therapy or disease natural history. Results in transplanted patients show continued neurocognitive and neurodevelopmental decline. The strength of the body of evidence is low.

Insufficient Evidence
- The strength of the body of evidence is insufficient to draw conclusions on the comparative benefit of single HSCT compared with symptom management and or disease natural history with respect to neurocognitive and neurodevelopmental outcomes for MPS IV (Morquio syndrome) and aspartylglucosaminuria.

No Evidence Found
- There was no evidence on single HSCT for Fabry's disease, β-mannosidosis, mucolipidosis III or IV, glycogen storage disease type II (Pompe disease), Salla disease, and adrenomyeloneuropathy.

### Disease With Both Rapidly and Slowly Progressive Forms

Evidence Suggesting Comparative Benefit of HSCT Over Conventional Therapy
- For single HSCT for Farber's disease Type 2/3. The evidence suggests a benefit for HSCT compared with symptom management or disease natural history. All five patients transplanted with type 2/3 showing a reduction in number of subcutaneous nodules and number of joints with limited range of motion at 0.7-1.3 years of followup. The strength of the body of evidence is high.

Evidence Suggesting No Comparative Benefit of HSCT Over Conventional Therapy
- For single HSCT for infantile ceroid lipofuscinosis. The evidence suggests no benefit for HSCT compared with symptom management or disease natural history with respect to neurocognitive outcomes. All three transplanted pediatric patients had neurocognitive decline and were hypotonic and spastic at 2-4 years followup. The strength of the body of evidence is moderate
- For single HSCT for Farber's disease type I (overall survival), juvenile form of GM_1_ (neurocognitive and neurodevelopmental), juvenile Tay-Sachs (neurocognitive and neurodevelopmental). The evidence suggests no benefit for HSCT compared with symptom management or disease natural history with respect to overall survival and/or neurocognitive and neurodevelopmental outcomes. Pediatric patients treated with HSCT showed similar decline and development to comparator patients. The strength of the body of evidence is low.

Insufficient Evidence
- The strength of the body of evidence is insufficient to draw conclusions on the comparative benefit of single HSCT compared with symptom management and or disease natural history with respect to overall survival and/or neurocognitive and neurodevelopmental measures for galactosialidosis (type unspecified) and Sandhoff disease (type unspecified).

No Evidence Found
- There was no evidence on single HSCT for infantile GM_1_ gangliosidosis, infantile Tay-Sachs and juvenile ceroid lipofuscinosis.

## Autoimmune Diseases (Key Questions 5 and 6)

Insufficient Evidence. The strength of evidence is insufficient to draw conclusions about the comparative effects of single HSCT and conventional therapy or disease natural history. In some diseases there is evidence that periods of drug free remission can be achieved. However, for all evaluated autoimmune diseases evidence was insufficient to evaluate the balance of long term benefits and harms. The autoimmune diseases evaluated in this report were: Type 1 diabetes mellitus, and severe/refractory systemic lupus erythematosus, juvenile idiopathic arthritis, systemic sclerosis, malignant multiple sclerosis, Crohn's disease, myasthenia gravis, overlap syndrome, diffuse cutaneous cutis, evans syndrome, autoimmune hemolytic anemia and autoimmune cytopenia.