# Key Questions From Comparative Effectiveness of HSCT for Pediatrics

Key Question 1. For pediatric patients with malignant solid tumors, what is the comparative effectiveness of HSCT and conventional chemotherapy regarding overall survival, long-term consequences of HSCT, and quality of life?

Key Question 2. For pediatric patients with malignant solid tumors, what are the comparative harms of HSCT and conventional chemotherapy regarding adverse effects of treatment, long term consequences of HSCT, and impaired quality of life?

Key Question 3. For pediatric patients with inherited metabolic diseases, what is the comparative effectiveness of HSCT, enzyme-replacement therapy (ERT), substrate reduction with iminosugars, and chaperones regarding overall survival, cure, long-term consequences of HSCT, and quality of life?

Key Question 4. For pediatric patients with inherited metabolic diseases, what are the comparative harms of HSCT, enzyme-replacement therapy (ERT), substrate reduction with iminosugars, and chaperones regarding adverse effects of treatment, long term consequences of HSCT, and impaired quality of life?

Key Question 5. For pediatric patients with autoimmune diseases, what is the comparative effectiveness of HSCT, immunosuppressants, target biologic therapies, and low dose chemotherapy regarding overall survival, cure, and remission?

Key Question 6. For pediatric patients with autoimmune diseases, what are the comparative harms of HSCT, immunosuppressants, target biologic therapies, and low dose chemotherapy regarding adverse effects of treatment, long term consequences of HSCT, and impaired quality of life?