# Acronyms

AHSCR: Autologous hematopoietic stem cell rescue
AHSCT: Autologous hematopoietic stem cell treatment
ASCR: Autologous stem cell rescue
CR: Complete remission
CSF: Cerebrospinal fluid
DOD: Dead of disease
EFS: Event-free survival
FU: Followup
HDCT: High-dose chemotherapy
HSCT: Hematopoietic stem cell treatment
OS: Overall survival
PBSCT: Peripheral blood stem-cell treatment
RBFS: Retinoblastoma-free survival
RFS: Relapse-free survival
SCT: Stem cell treatment
TRM: Treatment-related mortality