# Acknowledgments

The research team would like to acknowledge Sharon Flaherty, M.A., and Lisa Sarsany, M.A., for government contracts support and program management; Claudia J. Bonnell, B.S.N., M.L.S., and Kathleen M. Ziegler, Pharm.D., for reference and editorial management; and Kim Della Fave and Lisa Garofalo for administrative support.