# Results

We first describe the results of our process to generate the final list of research gaps (Steps 1 through 3). Subsequently, we describe the results of our prioritization of future research needs (Step 4), and suggest specific research designs.

## Step 1 Generating the Initial List of Evidence Gaps

The evidence gaps identified by the Stanford CER are listed in Table 1. Based on key informant input via a teleconference, we generated the initial list of evidence gaps (List 1 in Appendix B). Briefly, key informants underlined the importance of the subpopulations of elderly patients (older than 71 or even older than 75 years), women (who tend to have smaller body size), and subpopulations defined by racial descent (particularly Asian, who tend to have smaller body size), and diabetes (major comorbidity that needs further research).

They also added to the list of evidence gaps the subpopulations of patients with high body mass index (above 30kg/m^2^), heart failure (as ejection fraction less than 35 percent), and chronic renal disease prior to dialysis (stages 3 or 4). The rationale was that obese patients often have other comorbidities and can pose technical challenges to both revascularization options, and that both heart failure and chronic kidney disease may interact with treatment effects based on CAD pathophysiology.

In addition, key informants suggested that that there is little evidence on patients’ preferences regarding the revascularization procedures themselves, or the downstream outcomes with each procedure. For example, some patients may prefer the risk of a major surgery if they have a better chance to be relieved of anginal symptoms, even if they know that there is no evidence of difference in long term survival between CABG and PCI. The need for developing decision aids to facilitate shared decisionmaking by patients, those near them, and their physicians was also mentioned.

## Step 2 Generating the Expanded List of Evidence Gaps

The teleconference in Step 1 did not exhaust the discussion, and further input was sought in one-to-one interviews.^a^ To inform the discussion in the interviews we searched the literature to identify trials that have been published after the Stanford CER. We also searched ClinicalTrials.gov to identify ongoing studies in the field.

a Four out of six Key Informants participated in one-to-one interviews.

### Recently Published and Ongoing Studies

The literature search revealed new or ongoing trials relevant to two of the identified evidence gaps: the efficacy and safety of PCI vs. CABG for diabetics, and the relative efficacy and safety of DES vs. CABG.^b^ Five RCTs published after the completion of the Stanford CER generally used DES in their PCI arms, either exclusively, or in combination with BMS. None included balloon angioplasty. Two of the 5 RCTs included well over 1,500 patients;15,26 one included approximately 500 patients16 and the remaining two less than 200.^27,28^ Two of the largest RCTs enrolled only diabetic patients: CARDia compared DES or BMS with CABG16 while BARI 2D26 randomized patients to either prompt revascularization with intensive medical therapy vs. intensive medical therapy alone but stratified randomization by the choice of revascularization method (PCI vs. CABG). Two trials identified in ClinicalTrials.gov, FREEDOM23 (n=2400, NCT00086540) and VACARDS (n=790, NCT00326196)^c^ included only diabetic patients, suggesting that more data on diabetics will be available soon. The majority of ongoing trials used DES stents, again suggesting that additional evidence on DES vs. CABG will be available soon.

b Appendix Figure B1 presents the search flow and Appendix Table B1 summarizes their findings. Appendix Table B2 shows ongoing RCTs identified in ClinicalTrials.gov.

c ClinicalTrials.gov lists VACARDS as “terminated”, but offers no additional information. This may mean that the study has been terminated for efficacy, for futility, or because patient accrual was too slow.

### Expanded List of Research Gaps (List 2 in Appendix B)

Briefly, in one-to-one interviews, key informants suggested that the recently published and ongoing studies on diabetics are important, but do not necessarily attenuate the need for further research on the interaction of diabetes and treatment.

The previous list of evidence gaps (List 1) was further expanded to include the subpopulation of patients what have received prior revascularization procedures (PCI or CABG). The rationale was revascularization in these patients may pose technical challenges, and that these patients may be at different “baseline” risk than others. Regarding variants of revascularization procedures, key informants suggested focusing on PCI with DES and secondarily BMS; and on-pump traditional CABG with arterial grafts. The rationale was that these are the most commonly used procedures in current clinical practice and therefore should be the priority from a health system perspective. At the same time, it was appreciated that the comparative effectiveness of newer technologies such as PCI with bioabsorbable stents, or hybrid PCI and CABG approaches may be of immediate importance to payors, because they have to make coverage decisions even when evidence is incomplete.

Further, key informants suggested adding to the list several evidence gaps that were outside the scope of the Stanford CER. The first pertained to testing to guide choice of revascularization procedure (among patients in whom revascularization is warranted). The rationale was that testing may be able to predict differential response to PCI or CABG and therefore may result in better long term outcomes. A series of invasive and noninvasive tests were suggested, including invasive testing with coronary arteriography, non-invasive computerized tomography angiography (CTA) or magnetic resonance angiography (MRA), resting or exercise single photon emission computerized tomography (SPECT), noninvasive exercise treadmill testing with or without echocardiography. Second, key informants reiterated the importance of assessing patient preferences regarding revascularization procedures, and the importance of developing and evaluating decision aids to support shared decisionmaking. Finally, they suggested that an important evidence gap pertains to developing evidence-based performance measures.

The interim expanded list of evidence gaps (List 2) is provided in Appendix B.

## Step 3 Generating the Final List of Important Evidence Gaps

We pruned the interim list of evidence gaps (List 2) to contain its scope.^d^ We organized the final list of evidence gaps (Table 3, List 3 also shown in Appendix B) in to four thematic areas of future research. In the following paragraphs we justify our selections.

d This step was not anticipated in the beginning of the pilot project.

Table 3 Pruned (final) list of important evidence gaps

Thematic area | List of evidence gaps
Thematic area 1: Comparative effectiveness of PCI vs. CABG (Evidence gaps are formed by choosing a subpopulation and a comparison and evaluating all outcomes in the list) | Subpopulations:; - Age >75 years; - Prior PCI; - Diabetes; - Women; - Congestive heart failure; - Stage 3 or 4 of chronic kidney disease; Comparisons:; - BMS vs. on pump traditional CABG with arterial grafts; - DES vs. on pump traditional CABG with arterial grafts; Outcomes:; - 30-day outcomes-objective:; - Periprocedural death; - Nonfatal MI; - Nonfatal stroke; - Unplanned urgent revascularization with CABG during the PCI; - Renal failure requiring renal replacement therapy; - Post procedural discharge to rehabilitation facilities; - Health care costs; - Readmission rates for cardiac reasons such as heart failure and unstable angina; - Others like nosocomial infections are most relevant to CABG, and pulmonary complications affect the length of stay; - Intermediate outcomes (objective) at 1 year. The relative ranking would be similar to the applicable 30 day outcomes.; - Longer term outcomes (objective) would be 5 years. The relative ranking would be similar to the applicable 30 day outcomes.; - Subjective outcomes:; - QoL measured by generic or disease-specific instruments
Thematic area 2: Testing to inform choice of revascularization procedure | The evidence gap pertains to whether testing before revascularization can guide the choice of revascularization procedure, e.g., by predicting clinical response in the long term. Examples of invasive and non-invasive tests:; - Invasive coronary arteriography; - Non-invasive CTA or MRA; - Resting or exercise SPECT; - Exercise treadmill test with or without echocardiography
Thematic area 3: Enhancing patient participation | - Eliciting and measuring patient preferences; - Facilitating shared decisionmaking between patients and their physicians by developing and then evaluating decision support tools.
Thematic area 4: Assessing performance | - Based on prior key informant input, there are no validated process-based performance measures that could quantify optimal care

BMS=bare metal stents; CABG=coronary artery bypass grafting; CTA=computerized tomography-based angiography; DES=drug eluting stents; MI=myocardial infarction; MRA=magnetic resonance angiography; PCI=percutaneous coronary intervention; QoL=quality of life; SPECT=single photon emission computerized tomography

### Comparative Effectiveness of PCI vs. CABG (First Thematic Area)

We prioritized the patient subpopulations in the interim expanded list of the previous step (List 2) according to their relative frequency among patients who receive revascularization in the US (based on Hanan et al.,8 see also Appendix Table B3).^e^ The five most common patient groups are those listed in the first five bullets under the Subpopulations heading in Table 3. Especially for renal disease, the registries report only percentage with creatinine >2 or >2.5 mg/dL. In all likelihood this corresponds to stage 4 or stage 5 (renal replacement therapy). Stage 3 will be quite more frequent. Relying on prior key informant input, we included renal disease (stage 3 or 4) as a sixth most important subpopulation.

e The prevalence of a subpopulation was used as a crude proxy of “burden of disease.”

For PCI we considered angioplasty with BMS and angioplasty with DES. Although currently DES are much more commonly used compared to BMS, prior input from key informants suggested that BMS remain a PCI option that needs further consideration, especially in light of the higher DES costs. We excluded from further consideration balloon angioplasty, or other treatments that are not currently favored, such as brachytherapy. Based on prior input from key informants, we excluded bioabsorbable stents, because they are not yet routinely used and because there are a lot of remaining evidence gaps with DES and BMS already.

Based on prior input by key informants, for CABG, we considered the typical on-pump CABG with arterial grafts, which is the most common procedure. We did not prioritize minimally invasive coronary artery bypass (MIDCAB) or hybrid PCI and MIDCAB approaches because they are not used routinely, or they are used in very specific situations, respectively.

Regarding outcomes of interest, we prioritized clinical outcomes (subjective or objective, procedural, short term or long term) over surrogate measurements of revascularization success such as measurements of flow restoration or luminal diameter of revascularized vessels. It is desirable that future studies record as many of the outcomes in Table 3 as practically feasible.

### Testing To Inform Choice of Revascularization Procedure (Second Thematic Area)

The identified evidence gap pertains to the ability of several types of commonly available testing procedures to predict response with treatment (see Table 3). We do not refer to other settings such as screening of asymptomatic individuals, diagnosis, or treatment monitoring. In particular screening of asymptomatic individuals is an important research area, but it was deemed to be well outside the scope of the pilot project.

### Enhancing Patient Participation and Assessing Performance (Third and Fourth Thematic Areas)

The pertinent evidence gaps are listed in Table 3.

## Step 4 Recommendations for Future Research

We made recommendations for future research within the aforementioned thematic areas. The most elaborate prioritization was performed for the comparative effectiveness of PCI vs. CABG (first thematic area), as this is most directly related to the Stanford CER. The other three thematic areas were not in the scope of the Stanford CER, but represent important evidence gaps according to the assessments of the key informants and our team. In the following sections, we present our rationale for what future research to perform by thematic area of future research. The actual list of proposed future research is summarized in Table 4.

Table 4 Prioritized research designs to address future research needs when studying the comparative effectiveness of PCI and CABG

Thematic area | # | Population | Intervention | Comparator | - Primary outcomes; - Secondary outcomes | Design | Feasible | Research cost
(A) Comparative effectiveness and safety | 1 | General population of elderly patients >75 years old | On-pump CABG | PCI with DES (or with DES and BMS) | - Total mortality or composite of total mortality or myocardial infarctions; - Other objective and subjective outcomes | MIPD of RCT or registry data | Yes | Low
(A) Comparative effectiveness and safety | 1 | General population of elderly patients >75 years old | On-pump CABG | PCI with DES (or with DES and BMS) | - Total mortality or composite of total mortality or myocardial infarctions; - Other objective and subjective outcomes | Prospective comparative observational study, preferably nested in an existing cohort or registry | Yes | Medium
(A) Comparative effectiveness and safety | 1 | General population of elderly patients >75 years old | On-pump CABG | PCI with DES (or with DES and BMS) | - Total mortality or composite of total mortality or myocardial infarctions; - Other objective and subjective outcomes | RCT | Probably | High
(A) Comparative effectiveness and safety | 2^*^ | Heart failure | [As above] | [As above] | - Composite of total mortality or myocardial infarctions^†^; - Other objective and subjective outcomes | [same options as in row A1] | [same options as in row A1] | [same options as in row A1]
(A) Comparative effectiveness and safety | 3^*^ | Renal disease stage 3 or 4 | [As above] | [As above] | [As above] | [same options as in row A1] | [same options as in row A1] | [same options as in row A1]
(A) Comparative effectiveness and safety | 4 | Diabetes | [As above] | [As above] | [As above] | [same options as in row A1] | [same options as in row A1] | [same options as in row A1]
(B) Testing to predict treatment response | 1 | General population of revascularized patients | Invasive and noninvasive tests | Not applicable | Predictive sensitivity or specificity or related metrics | Retrospective analysis of RCT- based data | Yes | Low
(B) Testing to predict treatment response | 1 | General population of revascularized patients | Invasive and noninvasive tests | Not applicable | Predictive sensitivity or specificity or related metrics | Prospective cohort | Yes | Medium
(C) Enhancing patient participation | 1 | General population of revascularized patients | Not applicable | Not applicable | Description of patient preferences | Qualitative research | Yes | Low
(C) Enhancing patient participation | 1 | General population of revascularized patients | Not applicable | Not applicable | Description of patient preferences | Survey | Yes | Low
(C) Enhancing patient participation | 2 | General population of revascularized patients | Not applicable | Not applicable | Development of decision support tools | Qualitative research | Yes | Low or medium
(C) Enhancing patient participation | 2 | General population of revascularized patients | Not applicable | Not applicable | Evaluation of decision support tools | RCT | Unclear | Unclear
(D) Assessing performance | 1 | General population of revascularized patients | Not applicable | Not applicable | Development of evidence- based performance measures | Qualitative research; observational studies | Unclear | Unclear
(D) Assessing performance | 1 | General population of revascularized patients | Not applicable | Not applicable | Evaluation of systems that monitor performance | Before-after observational studies or cluster RCT | Unclear | Unclear

* so that power calculations result in a feasible trial (<2500 sample size).

BMS=bare metal stent; CABG=coronary artery bypass graft surgery; DES=drug eluting stent; MIPD=meta-analysis of individual patient data; RCT=randomized controlled trial.

### Comparative Effectiveness of PCI vs. CABG (First Thematic Area)

#### Summary of Key Informant Input

Figure 2 shows how key informants ranked the six priority subpopulations according to their perceived overall importance. Overall, the provided ranks suggest that the most important subpopulation is the elderly; followed by chronic kidney disease, heart failure, diabetes, and women; and finally those who had received prior revascularization with PCI. Some key informants noted that explicit ranking of subpopulations may be problematic, for several reasons. For example, one may suggest that almost all six subpopulations are equally important. Another explanation was that the populations are not mutually exclusive and therefore ranking them is not straightforward. On the other extreme, a key informant suggested that we probably do not have a good understanding of the real determinants of differential response to PCI or CABG. If for example the major determinant is the extent of the disease, more elaborate study of subpopulations defined by clinical characteristics, personal history or comorbidity will not be the most efficient way to advance knowledge.

Figure 2 Star graph of explicit ranking of six subpopulations by key informants

The figure consists of six panels, each corresponding to a subpopulation of interest. Each key informant is represented by an axis. All axes start from the center of the graph. Each key informant is denoted with a letter from “A” through “F” (the ordering of the letters does not correspond to the order they are mentioned in the text). The ranks they provided are listed on the corresponding axis as black dots. The furthest away a black dot is from the origin, the higher the rank. Some key informants provided tied ranks for some subpopulations. Red thick lines connect the black dots in adjacent axes forming polygons. Broadly speaking, for each subpopulation larger polygon areas tend to correspond to higher overall ranks. Key informant F opted not to provide the requested feedback. The ranks of key informant C were reconstructed based on the key informant’s rating in importance criteria per subpopulation (see Methods Section and Appendix B).

CKD=chronic kidney disease; HF=heart failure; PCI=percutaneous interventions; y=years.

Figure 2 is a representation of the research gaps listed in Table 1 within the context of the analytic framework described in Figure 1. Additional considerations presented in this figure include the impact of genetic differences on the patient/population, the impact of medication adherence and evidence-based use of angiotensin-converting enzyme (ACE) inhibitors/angiotensin II receptor blocker(s)/antagonist(s) (ARBs) on treatment outcomes and adverse events, and consideration of other medication classes as alternatives to ACE inhibitors/ARBs. The outcomes of interest have been expanded to include incidence of new diagnoses and utilization and cost of therapy. Angioedema has been added as an adverse event of interest. The impact of medication characteristics (dose response and class effect) on ACE inhibitor and ARB effectiveness or harms is also considered.

#### Focused Modeling To Identify Important Parameters in Future Studies in the First Thematic Area

Overall, in all three quantitative approaches (decision analysis, cost-effectiveness analysis and value of information analysis) the decision relevant quantity (quality adjusted life years, incremental cost effectiveness ratio and EVPPI, respectively) was mostly influenced by the uncertainty in the treatment effects between stenting with BMS, stenting with DES and CABG, particularly for the long term outcomes of death, myocardial infarction and stroke. The uncertainty around treatment effects for risk of repeat revascularization did not exert a large influence on the decision relevant quantities, apparently because these are already known with relative precision. Other quantities in the models (such as frequency of procedural events, treatment effects for procedural events, or utilities associated with different health states) exerted much smaller influence on the decision relevant quantities. These observations were consistent within each of the three modeled subpopulations we examined: the RCT-type participants, the population of elderly (over 75 years of age), and diabetics. Details of the quantitative analyses are presented in Appendix D.

EVPPI analyses that explicitly consider intervention costs, identified this as a set of parameters for which more information is needed. However, good information on average costs is straightforward to obtain in a specific setting, and therefore we do not consider costs as a target for future research.

For example, Figure 3 illustrates results of analyses on the expected value of perfect information for parameters for the model on elderly patients. (Analyses are qualitatively similar for the models on RCT-type patients and diabetics—see Appendix D.) The figure shows that the value of having perfect information is highest for 2 groups of parameters that stand for the relative effects between treatments for long term outcomes (deaths, myocardial infarctions, strokes and revascularizations). This suggests that future research should inform on the relative treatment effects between BMS, DES and CABG. This includes not only comparisons of BMS vs. CABG and DES vs. CABG, but comparisons of DES vs. BMS as well!^f^ However, the comparison between BMS and DES was outside the scope of the Stanford CER, and therefore we do not consider it further. We touch more on this issue in the Discussion Section.

f This is an important point. Because our models use CABG as the reference strategy, the relative effects between BMS and DES in our models are implicitly (indirectly) defined based on the relative effects of DES vs. CABG and of BMS vs. CABG. A different parameterization of the model (e.g., having DES as a reference) would show a high expected value of perfect information for parameters for DES vs. BMS.

Figure 3 Expected value of perfect information for groups of parameters over a range of cost-effectiveness thresholds

Shown are calculations of the expected value of perfect information for 6 groups of model parameters (EVPPI). Each group of parameters is represented by a line. The horizontal axis is the “willingness to pay” (cost-effectiveness threshold), i.e., the monetary equivalent of a quality-adjusted life year (QALY). The higher the expected value of perfect information for parameters, the more valuable future research that informs on these parameters is. Refer to Appendix D for more details on methods and complete results.

BMS=bare metal stents; DES=drug eluting stents; EVPPI=expected value of perfect information for parameters; PCI=percutaneous interventions; QALY=quality-adjusted life years; RR=relative risks.

Figure 3 is a representation of the process used for making recommendations for specific study designs. In general, the study design with the least risk of bias that can also feasibly address specific questions of interest is preferred. Starting with randomized controlled trials (RCTs), the applicability of a particular study design is considered in the context of a specific evidence gap until a reasonable balance is struck between risk of bias and practicality. In decreasing order of preference, study designs considered include RCTs, meta-analyses of RCTs, meta-analyses of observational studies, new observational studies specifically designed to address the evidence gap, analysis of existing observational data, and modeling studies. In some cases, modeling studies can be used to inform the design and evaluation of other study designs.

#### Candidate Study Designs

Modeling analyses suggest that the most influential parameters are the relative treatment effects, particularly for the long term outcomes of death, myocardial infarction and stroke, that is comparative evidence. As mentioned in Table 2 in the Methods Section, information on treatment effects (or on subpopulation-by-treatment interactions) is most efficiently obtained through a reanalysis of already compiled evidence. Another option is to perform de novo nonrandomized comparative studies, or preferably, to perform de novo RCTs (a more robust design).

Reanalyses of existing data should include all aforementioned outcomes, not only overall survival. Because of the eligibility criteria of existing efficacy RCTs, a meta-analysis of individual participant data from RCTs will not adequately represent older adults or patients with several comorbid conditions. Therefore, it is imperative to adequately study existing non-randomized data. In the field of coronary revascularization there is already a long experience with the use of data from large clinical registries. Capitalizing on the existing registries is probably one of the most efficient ways to provide more information for the identified research gaps. It is likely that to study the interaction of chronic kidney disease or heart failure with treatment, one may have to record more detailed information that that routinely deposited in the registries for a subset (perhaps a random sample) of registry patients. The associated expense for such research should be substantially lower than that of a de novo RCT.

Performing a meta-analysis (or reanalysis) of existing individual patient data from randomized trials or observational studies may be challenging, as several parties have to agree and collaborate. Another challenge is that studies may not have gathered data necessary for the analyses. If this is not feasible, one would have to obtain additional information by collecting new comparative data, namely through de novo nonrandomized comparative trials or through de novo RCTs. While randomized data are preferable, one may consider favoring a nonrandomized comparison as a first step, if it can be performed in a very efficient way. An example would be to “nest” the study in an ongoing registry. This way one would take advantage of the existing infrastructure of the ongoing registry to select and followup patients, and would collect additional clinical and other information on a subset of patients, as applicable.

De novo RCTs would ideally assess all outcomes of Table 3, or as many as practically feasible. However, is it realistic to consider a new RCT to compare PCI vs. CABG? Figure 4 helps put into perspective the feasibility of RCTs to address the identified research needs (Table 4). Based on Figure 4, if the 5-year rate of the primary event of interest in the comparator arms (controls) is 30 percent, a study of approximately 2,500 patients would attain 80 to 90 percent power to find a relative effect of 0.80 over 5 years of followup. The same study would attain a power of 60 percent over a 3 year followup. To get average followup duration of approximately 5 years a trial would have to go on for 6 to 8 years. Therefore, de novo RCTs are feasible, but would likely require resources comparable to recent large RCTs.

Figure 4 Power calculations for superiority RCTs for various 5-year primary event rates in the comparator arm

Plotted are power calculations for 6 different 5-year primary event rates in the comparator arm (5, 10, 15, 20, 30 and 40 percent, as shown next to each line in each panel). The calculations are for a two-sided chi-squared test at the 0.05 level of significance, and assuming a constant annual event rate, a true relative effect of 0.80 favoring the intervention arm, an allocation ratio of 1:1, no loss to follow up, no crossover between treatments, and no sequential monitoring. The gray area denotes sample sizes that may be too large (>2,500 patients total, see Methods Section). The red horizontal line stands for 90% power. Note that to get average followup duration of approximately 5 years a trial would have to go on for 6 to 8 years. This assumes a minimum followup of 2.5 years, a patient recruitment period of 5 years and a constant recruitment rate. In reality, the total sample size would have to be even larger than what is shown in the horizontal axis, as there will be loss to followup and there will also be adjustments for sequential monitoring.

In all likelihood, the primary outcome of a de novo RCT would have to be a composite outcome of death or myocardial infarction (to attain a high event rate). The exception is the subpopulation of elderly patients (older than 75 years), where event rates can be high enough for the outcome of death alone.

#### Recommended Future Research (Table 4)

We distinguish three tiers of pressing research needs in the first thematic area (Table 4). It is probably prudent to first perform reanalyses of existing data, and consider performing new RCTs only if existing data are not applicable to the population of interest, or suggest a subpopulation-by-treatment interaction that is clinically important. (Alternatively, one could perform efficient de novo nonrandomized comparative studies, as described above, and proceed to a de novo RCT only if there is suggestive evidence of an important treatment-by-subgroup interaction.) This is because, in all likelihood, a de novo RCT would require resources comparable to recent large multimillion dollar RCTs. Reanalyses of existing data could be collaborative meta-analyses of individual patient data from prior RCTs or from large observational studies, if the populations of interest are underrepresented in prior RCTs.

Currently, DES represent a more pressing research need compared to BMS, because they are used more often than BMS in everyday practice, and this trend will most likely continue in the midterm. The above does not mean that future studies should not use BMS. If numbers allow, an option would be to further randomize patients in the PCI arm to BMS vs. DES.

1. The first tier of future research studies are studies assessing the comparative effectiveness of PCI vs. CABG among the elderly, e.g., patients older than 75 years. Up to 40 percent of people who received revascularization in large registries were 75 years or older, but elderly patients are grossly underrepresented in the existing RCTs. In addition, there is evidence of strong age-by-treatment interaction. In a recent meta-analysis of individual patient data,^g^ survival was better with GABG compared with PCI for older patients (p-value for trend was 0.002 across the age categories of younger than 55, between 55 and65, and older than 65 years).17 The magnitude of the treatment effect modification was clinically significant, but it is unclear if it generalizes to older patients.
  g Data from this meta-analysis were used in our modeling.
2. The second tier of future research pertains to further study of patients with heart failure and patients with stage 3 or stage 4 renal disease. Although a recent meta-analysis of individual patient data found no significant interaction between heart failure and treatment effect for overall survival (p=0.46),17 patients with heart failure were excluded from many randomized trials that formed the basis of the meta-analysis. Thus we deem that the interaction of congestive heart failure and treatment choice remains unclear. We identified no analysis of randomized data on patients with chronic kidney disease.
3. The third tier pertains to studying the interaction of diabetic patients and treatment effects. There is already suggestive evidence that survival is better with CABG compared with PCI in diabetics (p=0.014 for treatment by diabetes interaction); such an interaction may be of substantial clinical significance if confirmed by further studies.17 However, at least two large ongoing trials, FREEDOM23 (n=2400, NCT00086540) and VACARDS (n=790, NCT00326196)^h^ included only diabetic patients. Their results will likely be presented within the next 2–3 years. In the light of this upcoming evidence we deemed that the need for additional data in diabetics is less pressing than that in the elderly.
  h ClinicalTrials.gov lists VACARDS as “terminated,” but offers no additional information. This may mean that the study has been terminated for efficacy, for futility, for safety, or because patient accrual was too slow.

Finally, we deemed that the subpopulation of women and people who have received PCI in the past represent less pressing priorities than the above, and do not recommend them as priority areas for future research. The previously mentioned meta-analysis of individual patient data found no interaction between sex and treatment effect (p=0.25) for overall survival.17 The meta-analysis did not report analyses with respect to having a prior revascularization, but key informants suggested that there is little if any evidence for an interaction of treatment with history of revascularization with PCI.

### Testing To Inform Treatment Choice (Second Thematic Area)

#### Summary of Key Informant Input

Key informants suggested that it is difficult to prioritize which baseline test or combination of tests is the best in predicting better response with CABG vs. PCI. This is not surprising, given that the Stanford CER did not review the role of testing in guiding treatment. However, key informants noted that if baseline (pre-revascularization) testing were able to predict long term differential response to PCI or CABG, its effects on patient health can be substantial. Overall, the key informants suggested that further elaboration of the ability of testing to affect clinical outcomes is highly desirable.

#### Candidate Study Designs

Ultimately, the clinical utility of medical tests is measured by whether the information they provide affects patient-relevant outcomes. To a large extent, effects of medical tests are indirect in nature.29 In principle, a test result affects patient outcomes mainly by influencing treatment choices. This indirectness in the link between testing and its downstream effects poses practical challenges to comparing alternate test-and-treat strategies in clinical trials.30

In theory, a large number of potential test-and-treat strategies could be considered, even if one is restricted to the four tests in Table 3. For example, one can explore using a single test, using several tests simultaneously, or using sequential testing (subsequent tests can be used to confirm the results of previous tests^i^; or earlier tests are used to triage who gets subsequent invasive testing^j^). In all these cases, one should also consider the threshold for test positivity. Each permutation of tests, test combinations and positivity thresholds represents a possible test-and-treat strategy. It is not possible to compare all test-and-treat strategies using RCTs.31 Instead, one should first quantify test performance in the clinical context of interest, and then assess the necessity of explicitly comparing test-and-treat strategies in RCTs. Based on the predictive accuracy of tests, one can deduce whether further study with an RCT of testing vs. no testing is mandatory, or whether a decision can be reached without further studies, following Lord et al.22

i This way the whole battery of tests enhances specificity.

j Especially if subsequent testing is invasive.

#### Recommended Future Research (Table 4)

Therefore, the most practical recommendation for future research is to explore the predictive accuracy (sensitivity and specificity) of the tests of interest^k^ or combinations thereof by performing cohort studies, case control studies, or by reanalyzing baseline data from existing RCTs (if available). To be clinically useful and informative, such studies should enroll patients representative of those seen in clinical practice, and limit verification and other biases.32,33 Such studies should be relatively feasible given the high prevalence of the conditions of interest, the widespread availability of most diagnostic technologies considered by the key informants, and the fact that most patients treated with PCI or CABG already receive extensive workup before their revascularization.

k Here, arteriography, MRA or CTA, resting or exercise SPECT, exercise treadmill testing with or without echocardiography.

### Enhancing Patient Participation (Third Thematic Area)

#### Summary of Key Informant Input

Input from key informants suggested that life expectancy is not the only outcome that matters to patients and those close to them. While the importance of quality of life is generally appreciated by physicians and decisionmakers it is not always clear whether, how, and to which extent it is considered. For example, a key informant suggested that current clinical practice guidelines seem to focus on life expectancy, without giving substantial weight to e.g., the likelihood of symptoms after revascularization (i.e., to quality-adjusted life expectancy).

Key informants pointed out the need for development and evaluation of decision aids, to facilitate shared decisionmaking. At the same time, it was appreciated that shared decisionmaking is probably not the norm in current clinical practice in PCI vs. CABG. In practice, a physician could sway a patient’s choice by focusing on the pros or cons of either treatment. A desire of patients for ultimate treatment decisions regarding CAD treatment to be made by doctors has been observed in empirical studies.34 Therefore, a major issue is not only the development, but also the evaluation of decision aids in real-life clinical settings.

#### Candidate Study Designs

Although the importance of considering patient preferences in treatment decisions is well recognized,35,36 it is unclear what the best approach for developing decision support tools is. A primary reason for this is the presence of multiple gaps in research for such aids: little is known about their actual effects across different decisional contexts, their acceptability to patients and physicians, or their potential effects on health-related quality of life. In addition, the development, dissemination and implementation of decision support tools are fraught with substantial methodological challenges. These challenges include the de facto inability to evaluate decision aids in double-blind trials, potential selection biases due to physicians’ preconceptions (either positive or negative) and difficulties in reliably measuring the impact of decision support tools on clinical outcomes.

O’Connor et al.37 discussed the research and policy implications of developing decision support tools with a focus on the challenges of designing future studies. If strong candidate decision aids for patient decisionmaking were available, then randomized trials, preferably randomizing physicians (rather than the individual patients they care for) to either employing or not employing decision aids (i.e., with cluster RCTs), would provide an optimal but possibly costly method of evaluating their effects on clinical outcomes.38

#### Recommended Future Research (Table 4)

A suitable study design to elicit patient preferences is a survey of patients, or a qualitative research study that uses focus groups of patients. It is at best unclear whether a study of patient preferences will have a major impact on the remaining research agenda. However, compared to designing and undertaking a new RCT, such studies on patient preferences are quite feasible, and relatively inexpensive.

A suitable study design to develop a decision aid is a qualitative research study that uses focus groups of patients, relatives of patients, and physicians. Based on key informant input, there are no decision aids in routine clinical use. Therefore, the question of evaluating decision aims may be premature.

### Assessing Performance (Fourth Thematic Area)

#### Summary of Key Informant Input

All key informants agreed that development of evidence-based performance measures, monitoring of practice based on these measures and providing feedback to health care facilities and practitioners can improve revascularization outcomes and may reduce inequalities in provided health care at the national level.

#### Candidate Study Designs

In principle, it should be feasible to identify process-based measures of performance in cardiovascular care, as there are a lot of interventions with strong support from RCTs in the domain of cardiovascular disease. Evidence suggests that establishing performance measures and active monitoring of physician performance has positive impact on the quality of delivered health care.39 However, for most chronic diseases, including CAD, it is not possible to use simple “all-or-nothing” measures to quantify optimal care; simple measures are limited to quantifying poor care.40 Therefore, developing evidence-based performance measures for major diseases can be considered as a priority for a health system, as it carries the promise of reducing inequalities in health care access and delivery.

It is not clear what the optimal study design is for developing process-based performance measures.41 One would have to define the exact details of the clinical area to be measured, select key aspects of care for measurement, design specifications for the measures, develop a data collection strategy, test the scientific strength (validity, reliability, feasibility) of the measures, and then monitor practice and provide feedback.42–44

It appears that to develop performance measures one option is to perform qualitative research where focus groups of scientists with relevant expertise would propose specific measures based on the current evidence base and analyses of administrative data. Health care professionals as well as investigators with expertise in bioinformatics, quality control, or operations research would offer complementary expertise. To inform these focus groups it may be important to conduct analyses of administrative data related to the processes of interest.

The actual evaluation of whether the implementation of a performance monitoring and feedback system could be readily performed in observational studies that measure performance before and after the implementing the monitoring and feedback mechanism. A much stronger design would be a cluster RCT, where one would randomize health care facilities to implement versus not implement the system. However, unless there is substantial infrastructure already in place, such a cluster RCT would not be easy to perform.

#### Recommended Future Research (Table 4)

The optimal research design to develop reliable process-based measures of performance is not clear. One option is to perform qualitative research using focus groups of health care professionals as well as participants with expertise in bioinformatics, quality control or operations research. Evaluating process-based performance measures would be typically performed in large-scope studies that analyze administrative data before and after the implementation of performance monitoring and feedback systems, or in large cluster-randomized trials.