# References

1 Coronary artery bypass surgery versus percutaneous coronary intervention with stent implantation in patients with multivessel coronary artery disease (the Stent or Surgery trial): a randomised controlled trial. Lancet. Sept. 28. 2002;360(9338):965-970. [pmid: 12383664].
2 The final 10-year follow-up results from the BARI randomized trial. J Am Coll Cardiol. Apr. 17. 2007;49(15):1600-1606. [pmid: 17433949].
3 Henderson RA, Pocock SJ, Sharp SJ, et al. Long-term results of RITA-1 trial: clinical and cost comparisons of coronary angioplasty and coronary-artery bypass grafting. Randomised Intervention Treatment of Angina. Lancet. Oct. 31. 1998;352(9138):1419-1425. [pmid: 9807988].
4 Hueb W, Lopes NH, Gersh BJ, et al. Five-year follow-up of the Medicine, Angioplasty, or Surgery Study (MASS II): a randomized controlled clinical trial of 3 therapeutic strategies for multivessel coronary artery disease. Circulation. Mar. 6. 2007;115(9):1082-1089. [pmid: 17339566].
5 Hueb WA, Bellotti G, de Oliveira SA, et al. The Medicine, Angioplasty or Surgery Study (MASS): a prospective, randomized trial of medical therapy, balloon angioplasty or bypass surgery for single proximal left anterior descending artery stenoses. J Am Coll Cardiol. Dec. 1995;26(7):1600-1605. [pmid: 7594092].
6 Sedlis SP, Ramanathan KB, Morrison DA, et al. Outcome of percutaneous coronary intervention versus coronary bypass grafting for patients with low left ventricular ejection fractions, unstable angina pectoris, and risk factors for adverse outcomes with bypass (the AWESOME Randomized Trial and Registry). Am J Cardiol. Jul. 1. 2004;94(1):118-120. [pmid: 15219521].
7 Serruys PW, Ong AT, van Herwerden LA, et al. Five-year outcomes after coronary stenting versus bypass surgery for the treatment of multivessel disease: the final analysis of the Arterial Revascularization Therapies Study (ARTS) randomized trial. J Am Coll Cardiol. Aug. 16. 2005;46(4):575-581. [pmid: 16098418].
8 Hannan EL, Racz MJ, Walford G, et al. Long-term outcomes of coronary-artery bypass grafting versus stent implantation. N Engl J Med. May. 26. 2005;352(21):2174-2183. [pmid: 15917382].
9 Malenka DJ, Leavitt BJ, Hearne MJ, et al. Comparing long-term survival of patients with multivessel coronary disease after CABG or PCI: analysis of BARI-like patients in northern New England. Circulation. Aug. 30. 2005;112(9 Suppl):I371-I376. [pmid: 16159849].
10 Pell JP, Walsh D, Norrie J, et al. Outcomes following coronary artery bypass grafting and percutaneous transluminal coronary angioplasty in the stent era: a prospective study of all 9890 consecutive patients operated on in Scotland over a two year period. Heart. Jun. 2001;85(6):662-666. [pmid: 11359748].
11 Dzavik V, Ghali WA, Norris C, et al. Long-term survival in 11,661 patients with multivessel coronary artery disease in the era of stenting: a report from the Alberta Provincial Project for Outcome Assessment in Coronary Heart Disease (APPROACH) Investigators. Am Heart J. Jul. 2001;142(1):119-126. [pmid: 11431667].
12 Bravata D, McDonald K, Gienger A, et al. Comparative effectiveness of percutaneous coronary interventions and coronary artery bypass grafting for coronary artery disease, Comparative Effectiveness Review No 9 (prepared by Stanford UCSF-EPC). 2007.
13 Boden WE, O’Rourke RA, Teo KK, et al. Optimal medical therapy with or without PCI for stable coronary disease. N Engl J Med. Apr. 12. 2007;356(15):1503-1516. [pmid: 17387127].
14 Trikalinos TA, Alsheikh-Ali AA, Tatsioni A, et al. Percutaneous coronary interventions for non-acute coronary artery disease: a quantitative 20-year synopsis and a network meta-analysis. Lancet. Mar. 14. 2009;373(9667):911-918. [pmid: 19286090].
15 Serruys PW, Morice MC, Kappetein AP, et al. Percutaneous coronary intervention versus coronary-artery bypass grafting for severe coronary artery disease. N Engl J Med. Mar. 5. 2009;360(10):961-972. [pmid: 19228612].
16 Kapur A, Hall RJ, Malik IS, et al. Randomized comparison of percutaneous coronary intervention with coronary artery bypass grafting in diabetic patients. 1-year results of the CARDia (Coronary Artery Revascularization in Diabetes) trial. J Am Coll Cardiol. Feb. 2. 2010;55(5):432-440. [pmid: 20117456].
17 Hlatky MA, Boothroyd DB, Bravata DM, et al. Coronary artery bypass surgery compared with percutaneous coronary interventions for multivessel disease: a collaborative analysis of individual patient data from ten randomised trials. Lancet. Apr. 4. 2009;373(9670):1190-1197. [pmid: 19303634].
18 Rao C, Aziz O, Panesar SS, et al. Cost effectiveness analysis of minimally invasive internal thoracic artery bypass versus percutaneous revascularisation for isolated lesions of the left anterior descending artery. BMJ. Mar. 24. 2007;334(7594):621. [pmid: 17337457].
19 Yock CA, Boothroyd DB, Owens DK, et al. Cost-effectiveness of bypass surgery versus stenting in patients with multivessel coronary artery disease. Am J Med. Oct. 1. 2003;115(5):382-389. [pmid: 14553874].
20 Bischof M, Briel M, Bucher HC, et al. Cost-Effectiveness of Drug-Eluting Stents in a US Medicare Setting: A Cost-Utility Analysis with 3-Year Clinical Follow-Up Data. Value Health. 2009. Mar. 11.
21 Lumley T. Network meta-analysis for indirect treatment comparisons. Stat Med. Aug. 30. 2002;21(16):2313-24. [pmid: 12210616].
22 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials. Ann Intern Med. Jun. 6. 2006;144(11):850-855. [pmid: 16754927].
23 Farkouh ME, Dangas G, Leon MB, et al. Design of the Future REvascularization Evaluation in patients with Diabetes mellitus: Optimal management of Multivessel disease (FREEDOM) Trial. Am Heart J. Feb. 2008;155(2):215-223. [pmid: 18215589].
24 Jones RH, Velazquez EJ, Michler RE, et al. Coronary bypass surgery with or without surgical ventricular reconstruction. N Engl J Med. Apr. 23. 2009;360(17):1705-1717. [pmid: 19329820].
25 Velazquez EJ, Lee KL, O’Connor CM, et al. The rationale and design of the Surgical Treatment for Ischemic Heart Failure (STICH) trial. J Thorac Cardiovasc Surg. Dec. 2007;134(6):1540-1547. [pmid: 18023680].
26 Frye RL, August P, Brooks MM, et al. A randomized trial of therapies for type 2 diabetes and coronary artery disease. N Engl J Med. Jun. 11. 2009;360(24):2503-2515. [pmid: 19502645].
27 Buszman P, Wiernek S, Szymanski R, et al. Percutaneous versus surgical revascularization for multivessel coronary artery disease: a single center 10 year follow-up of SOS trial patients. Catheter Cardiovasc Interv. Sept. 1. 2009;74(3):420-426. [pmid: 19360866].
28 Thiele H, Neumann-Schniedewind P, Jacobs S, et al. Randomized comparison of minimally invasive direct coronary artery bypass surgery versus sirolimus-eluting stenting in isolated proximal left anterior descending coronary artery stenosis. J Am Coll Cardiol. Jun. 23. 2009;53(25):2324-2331. [pmid: 19539141].
29 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. Apr. 1991;11(2):88-94. [pmid: 1907710].
30 Lijmer JG, Leeflang M, Bossuyt PM. Proposals for a phased evaluation of medical tests. Med Decis Making. Sept. 2009;29(5):E13-E21. [pmid: 19605881].
31 Trikalinos TA, Siebert U, Lau J. Decision-analytic modeling to evaluate benefits and harms of medical tests: uses and limitations. Med Decis Making. Sept. 2009;29(5):E22-E29. [pmid: 19734441].
32 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. Sept. 15. 1999;282(11):1061-1066. [pmid: 10493205].
33 Rutjes AW, Reitsma JB, Di NM, et al. Evidence of bias and variation in diagnostic accuracy studies. CMAJ. Feb. 14. 2006;174(4):469-476. [pmid: 16477057].
34 Lambert N, Rowe G, Bowling A, et al. Reasons underpinning patients' preferences for various angina treatments. Health Expect. Sept. 2004;7(3):246-256. [pmid: 15327463].
35 Kassirer JP. Adding insult to injury. Usurping patients' prerogatives. N Engl J Med. Apr. 14. 1983;308(15):898-901. [pmid: 6835288].
36 Kassirer JP. Incorporating patients’ preferences into medical decisions. N Engl J Med. Jun. 30. 1994;330(26):1895-1896. [pmid: 8196734].
37 O’Connor AM, Fiset V, DeGrasse C, et al. Decision aids for patients considering options affecting cancer outcomes: evidence of efficacy and policy implications. J Natl Cancer Inst Monogr. 1999:67-80. [pmid: 10854460].
38 O’Connor AM, Bennett CL, Stacey D, et al. Decision aids for people facing health treatment or screening decisions. Cochrane Database Syst Rev. Jul. 2009;8(3):CD001431. [pmid: 19588325].
39 Asch SM, McGlynn EA, Hogan MM, et al. Comparison of quality of care for patients in the Veterans Health Administration and patients in a national sample. Ann Intern Med. Dec. 21. 2004;141(12):938-945. [pmid: 15611491].
40 Hayward RA. All-or-nothing treatment targets make bad performance measures. Am J Manag Care. Mar. 2007;13(3):126-128. [pmid: 17335355].
41 Eddy DM. Performance measurement: problems and solutions. Health Aff (Millwood ). Jul. 1998;17(4):7-25. [pmid: 9691542].
42 Golden WE, Hermann RC, Jewell M, et al. Development of evidence-based performance measures for bipolar disorder: overview of methodology. J Psychiatr Pract. May. 2008;14(Suppl 2):18-30. [pmid: 18677196].
43 Groce JB III. Translating evidence-based guidelines into performance measures for venous thromboembolism and acute coronary syndrome. Am J Health Syst Pharm. Jun. 1. 2007;64(11 Suppl 7):S25-S29. [pmid: 17519443].
44 van Gaal BG, Schoonhoven L, Hulscher ME, et al. The design of the SAFE or SORRY? study: a cluster randomised trial on the development and testing of an evidence based inpatient safety program for the prevention of adverse events. BMC Health Serv Res. 2009;9:58. [pmid: 19338655].
45 Kellum JA, Mehta RL, Levin A, et al. Development of a clinical research agenda for acute kidney injury using an international, interdisciplinary, three-step modified Delphi process. Clin J Am Soc Nephrol. May. 2008;3(3):887-894. [pmid: 18216348].
46 Oliver S, Clarke-Jones L, Rees R, et al. Involving consumers in research and development agenda setting for the NHS: developing an evidence-based approach. Health Technol Assess. Apr. 2004;8(15):1-IV. [pmid: 15080866].
47 O’Donnell M, Entwistle V. Consumer involvement in decisions about what health-related research is funded. Health Policy. Dec. 2004;70(3):281-290. [pmid: 15488995].
48 Herxheimer A. Relationships between the pharmaceutical industry and patients' organisations. BMJ. May. 31. 2003;326(7400):1208-1210. [pmid: 12775627].
49 Vella K, Goldfrad C, Rowan K, et al. Use of consensus development to establish national research priorities in critical care. BMJ. Apr. 8. 2000;320(7240):976-980. [pmid: 10753149].
50 van der Beek AJ, Frings-Dresen MH, van Dijk FJ, et al. Priorities in occupational health research: a Delphi study in The Netherlands. Occup Environ Med. Jul. 1997;54(7):504-510. [pmid: 9282128].
51 Harrington JM, Calvert IA. Research priorities in occupational medicine: a survey of United Kingdom personnel managers. Occup Environ Med. Sept. 1996;53(9):642-644. [pmid: 8882122].
52 Brittenham GM, Franks AL, Rickles FR. Research priorities in hereditary hemochromatosis. Ann Intern Med. Dec. 1. 1998;129(11):993-996. [pmid: 9867753].
53 Chestnutt IG, Taylor MM. Prioritisation of research recommendations from a national needs assessment programme. Health Bull (Edinb). Sept. 2000;58(5):396-402. [pmid: 12813793].
54 Bond S, Bond J. A Delphi survey of clinical nursing research priorities. J Adv Nurs. November. 1982;7(6):565-75. [pmid: 6759554].
55 Schmidt K, Montgomery LA, Bruene D, et al. Determining research priorities in pediatric nursing: a Delphi study. J Pediatr Nurs. Aug. 1997;12(4):201-207. [pmid: 9271880].
56 Dunn VH, Moskowitz AJ, Lau J, et al. Can “hypersimplified” decision trees be used instead of Markov models? [ABSTRACT]. Med Decis Making. 1984;4.
57 Claxton K, Ginnelly L, Sculpher M, et al. A pilot study on the use of decision theory and value of information analysis as part of the NHS Health Technology Assessment programme. Health Technol Assess. Jul. 2004;8(31):1-103. iii. [pmid: 15248937].
58 Claxton KP, Sculpher MJ. Using value of information analysis to prioritise health research: some lessons from recent UK experience. Pharmacoeconomics. 2006;24(11):1055-1068. [pmid: 17067191].
59 Briggs A, Claxton K, Schulpher M. Decision modelling for health economic evaluation. Oxford. Oxford University Press. 2006.
60 Ades AE, Cliffe S. Markov chain Monte Carlo estimation of a multiparameter decision model: consistency of evidence and the accurate assessment of uncertainty. Med Decis Making. Jul. 2002;22(4):359-371. [pmid: 12150601].
61 Neumann PJ, Greenberg D. Is the United States ready for QALYs?. Health Aff (Millwood). Sept. 2009;28(5):1366-1371. [pmid: 19738253].
62 Neumann PJ. Why don’t Americans use cost-effectiveness analysis?. Am J Manag Care. May. 2004;10(5):308-312. [pmid: 15152700].