# Executive Summary

The Effective Health Care Program was initiated in 2005 to provide valid evidence about the comparative effectiveness of different medical interventions. The object is to help consumers, health care providers, and others in making informed choices among treatment alternatives. Through its comparative effectiveness reviews, the program supports systematic appraisals of existing scientific evidence regarding treatments for high-priority health conditions. It also promotes and generates new scientific evidence by identifying gaps in existing scientific evidence and supporting new research. The program puts special emphasis on translating findings into a variety of useful formats for different stakeholders, including consumers.

The full report and this summary are available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.

## Background

Percutaneous coronary interventions (PCI) with or without stents and coronary artery bypass graft surgery (CABG) are the two broad categories of interventions for mechanical revascularization of atherosclerotic coronary arteries in patients with coronary artery disease (CAD). Generally, both approaches would be clinically relevant for patients with single-vessel disease of the proximal left anterior descending artery, most types of two-vessel disease, as well as for patients with three-vessel disease that is not particularly extensive. Because PCI and CABG differ in their procedural risk and their initial and downstream costs, assessing their comparative effectiveness and safety is of great interest.

PCI and CABG have already been compared in several randomized controlled trials (RCTs) and analyses of large clinical registries. The aim of this report is to identify needs for future research in the comparison between PCI and CABG. We use as a basis the 2007 comparative effectiveness review (CER) by the Stanford–University of California at San Francisco Evidence-based Practice Center (Stanford–UCSF EPC) that assessed PCI vs. CABG for coronary artery disease (hereafter we refer to the report as the “Stanford CER” for brevity). The CER summarized evidence published through 2006. Table I lists the key questions of the CER and a qualitative synopsis of the findings:

Table I Summary of findings of the Stanford CER

Key Question | Summary of findings
In patients with ischemic heart disease and angiographically proven single- or multiple- vessel disease, what is the comparative effectiveness of PCI compared to CABG in reducing the occurrence of adverse objective outcomes and improving subjective outcomes? Over what period are the comparative benefits of PCI and CABG sustained? | Procedural survival was high for both interventions and was not significantly different between PCI and CABG. Freedom from procedural strokes significantly favored PCI compared to CABG, but freedom from procedural myocardial infarction was heterogeneously defined and was not significantly different between the two treatments. Long-term survival was significantly better for CABG compared to PCI in the older trials (pre 1994, where PCI was mostly balloon angioplasty). However, long term survival was not significantly different between CABG and PCI trials in the stent era. Freedom from myocardial infarction was not statistically significant between the compared treatments. Regarding long-term subjective outcomes, freedom from angina was greater for CABG rather than PCI interventions. Quality of life outcomes favored CABG over PCI between 6 months and 3 years of followup but equalized thereafter. The degree of improvement in quality of life was correlated with relief of angina.
Is there evidence that the comparative effectiveness of PCI and CABG varies based on (predefined) patient and procedure related factors? | The Stanford CER evaluated the evidence for comparative effectiveness of PCI and CABG based on (predefined) patient-, provider-, disease- and intervention- related factors. However, the report noted that in contrast to the fairly robust evidence concerning overall clinical outcomes, there was much less evidence from randomized trials to gauge whether and how comparative effectiveness varied across these factors. Most clinical trials reported only on survival and not on other outcomes in key patient subpopulations.

CABG=coronary artery bypass surgery; CER=comparative effectiveness review PCI=percutaneous coronary intervention

The Stanford CER includes almost all large RCTs that are available as of this writing. It is therefore a relatively current report. However two limitations should be noted. Medical treatment (no revascularization) is now considered a clinically valid option for many patients with nonacute CAD, but it was not in the scope of the Stanford CER. Therefore the Stanford CER does not represent a full evaluation of the actual clinical options that are available today. Second, several RCTs have published their results after the completion of the Stanford CER and several ongoing RCTs are expected to report results in the next 2 or 3 years. This means that the following evidence gaps identified in the Stanford CER should be assessed in the light of the newer evidence. The identified gaps were:

1. Paucity of published analyses of PCI and CABG outcomes according to patient characteristics. Specifically highlighted subgroups include women, the elderly, patients with chronic kidney disease, and patients with left ventricular dysfunction.
2. Paucity of data on the comparative effectiveness and safety of drug eluting stents (DES) in particular, and especially in the long term.
3. Paucity of data on the relationship between procedural volume and outcomes of minimally invasive approaches to CABG. It cannot be assumed that the relationships defined for standard CABG will apply to minimally invasive CABG. For example, the volume thresholds of minimally invasive CABG may differ, given the differences in the technique.
4. Paucity of data on metrics for quality of care for PCI and CABG procedures.

## Methods

We aimed for a practical approach to identifying evidence gaps and prioritizing them into research needs. This approach was based on combining limited stakeholder input, focused searches of the literature, and results of simple modeling to derive a prioritized list of research needs which could then be fitted to possible research designs. We focused on the comparison of PCI interventions and CABG in patients with nonacute CAD in whom revascularization is warranted because of their symptoms or because of the extent of their disease.

We followed an iterative process to compile a list of important evidence gaps. First, we generated an initial list of evidence gaps based on the Stanford CER and initial feedback from a group of key informants. Subsequently, we searched the literature to identify trials that have been published after the Stanford CER, and ClinicalTrials.gov to identify ongoing studies in the field. Taking into account the results of the literature searches, we proceeded to further refine the initial list of evidence gaps in one-to-one interviews with key informants. This resulted in an interim expanded list of evidence gaps, which was pruned according to post hoc criteria, but without direct and explicit feedback from stakeholders. This pruning step was not anticipated in the beginning of the pilot project but it was considered necessary in view of the expansion of the evidence gaps list at the prior steps.

We classified evidence gaps into four thematic areas of future research that are not overlapping, could be pursued independently, and are amenable to different types of study designs (and therefore do not all require extensive resources to pursue):

A. The comparative effectiveness and safety of PCI vs. CABG
B. The role of testing to inform choice of revascularization procedure
C. Methods for enhancing patient participation
D. Methods for assessing performance

Only the first thematic area was directly related to the scope of the Stanford CER. The other three thematic areas were added based on key informant input.

We then recommended specific research designs for the most important evidence gaps within each thematic area. To this end we assessed the importance of each evidence gap, estimated the feasibility of different research designs, asked for additional key informant feedback, and performed focused modeling analyses to pinpoint for which parameters it is most important to obtain additional information through future research.

Specifically, we considered the following ad hoc criteria to prioritize research needs: feasibility in terms of research costs, feasibility in terms of projected study duration, likelihood that the study will have nontrivial findings, likelihood that the study will provide unbiased results (to inform clinical practice), and likelihood that ongoing research will address the evidence gap. We considered that a new study would be infeasible if it were too expensive or complex to conduct, if it required too long a followup (beyond 5–7 years), or if it relied on information or data that is not yet available. Generally, RCTs are among the most expensive research designs. Some of the largest recent efficacy RCTs in nonacute CAD have sample sizes in the neighborhood of 2,500 patients. Using this as a reference, we commented on the feasibility of other research designs. We performed sample size calculations using standard formulae for a two-sided, chi-squared test at the 0.05 level of significance.

For research needs falling in the first thematic area (comparative effectiveness of PCI vs. CABG) we also performed focused modeling to pinpoint which parameters are most important to study in future research.^a^ We developed simple decision models that compare different revascularization options in typical RCT participants, elderly patients (older than 75 years), and diabetics. Estimates for model parameters were derived from published sources. We used network meta-analysis to obtain consistent estimates for all treatment effects. We used different types of analyses (decision analysis, cost-effectiveness analysis, and value of information analysis) to identify the most influential parameters in the models.

a Assuming a reasonably simple specification of this decisional problem, such parameters may be the prevalence of procedural deaths or procedural strokes; the relative effects for procedural deaths or strokes across the compared interventions; the frequency of long term deaths, myocardial infarctions, strokes, or repeat revascularizations; the corresponding relative effects across revascularization options; patient preferences (utilities); and immediate and downstream health care costs. This has practical implications, because different parameters are naturally amenable to different research designs.

## Results

We present our recommendations for future research in each thematic area (Table II). Only the first thematic area was in the scope of the Stanford CER, and, thus, there are limitations to our research recommendations for the last three thematic areas. This is because we did not have the benefit of a thorough evaluation of the literature, and it is possible that the identified evidence gaps have been addressed.

Table II Prioritized research designs to address future research needs when studying the comparative effectiveness of PCI and CABG

Thematic area | # | Population | Intervention | Comparator | - Primary outcomes; - Secondary outcomes | Design | Feasible | Research cost
(A) Comparative effectiveness and safety | 1 | General population of elderly patients >75 years old | On-pump CABG | PCI with DES (or with DES and BMS) | - Total mortality or composite of total mortality or myocardial infarctions; - Other objective and subjective outcomes | MIPD of RCT or registry data | Yes | Low
(A) Comparative effectiveness and safety | 1 | General population of elderly patients >75 years old | On-pump CABG | PCI with DES (or with DES and BMS) | - Total mortality or composite of total mortality or myocardial infarctions; - Other objective and subjective outcomes | Prospective comparative observational study, preferably nested in an existing cohort or registry | Yes | Medium
(A) Comparative effectiveness and safety | 1 | General population of elderly patients >75 years old | On-pump CABG | PCI with DES (or with DES and BMS) | - Total mortality or composite of total mortality or myocardial infarctions; - Other objective and subjective outcomes | RCT | Probably | High
(A) Comparative effectiveness and safety | 2^*^ | Heart failure | [As above] | [As above] | - Composite of total mortality or myocardial infarctions^†^; - Other objective and subjective outcomes | [same options as in row A1] | [same options as in row A1] | [same options as in row A1]
(A) Comparative effectiveness and safety | 3^*^ | Renal disease stage 3 or 4 | [As above] | [As above] | [As above] | [same options as in row A1] | [same options as in row A1] | [same options as in row A1]
(A) Comparative effectiveness and safety | 4 | Diabetes | [As above] | [As above] | [As above] | [same options as in row A1] | [same options as in row A1] | [same options as in row A1]
(B) Testing to predict treatment response^‡^ | 1 | General population of revascularized patients | Invasive and noninvasive tests | Not applicable | Predictive sensitivity or specificity or related metrics | Retrospective analysis of RCT- based data | Yes | Low
(B) Testing to predict treatment response^‡^ | 1 | General population of revascularized patients | Invasive and noninvasive tests | Not applicable | Predictive sensitivity or specificity or related metrics | Prospective cohort | Yes | Medium
(C) Enhancing patient participation^‡^ | 1 | General population of revascularized patients | Not applicable | Not applicable | Description of patient preferences | Qualitative research | Yes | Low
(C) Enhancing patient participation^‡^ | 1 | General population of revascularized patients | Not applicable | Not applicable | Description of patient preferences | Survey | Yes | Low
(C) Enhancing patient participation^‡^ | 2 | General population of revascularized patients | Not applicable | Not applicable | Development of decision support tools | Qualitative research | Yes | Low or medium
(C) Enhancing patient participation^‡^ | 2 | General population of revascularized patients | Not applicable | Not applicable | Evaluation of decision support tools | RCT | Unclear | Unclear
(D) Assessing performance^‡^ | 1 | General population of revascularized patients | Not applicable | Not applicable | Development of evidence- based performance measures | Qualitative research; observational studies | Unclear | Unclear
(D) Assessing performance^‡^ | 1 | General population of revascularized patients | Not applicable | Not applicable | Evaluation of systems that monitor performance | Before-after observational studies or cluster RCT | Unclear | Unclear

BMS=bare metal stent; CABG=coronary artery bypass graft surgery; DES=drug eluting stent; MIPD=meta-analysis of individual patient data; RCT=randomized controlled trial.

* We considered heart failure and renal disease as equally pressing needs.

† So that power calculations result in a feasible trial (<2500 sample size).

‡ A thorough evaluation of the literature for these research gaps was not available (they were not included in the Stanford CER).

### Comparative Effectiveness of PCI vs. CABG (First Thematic Area)

We distinguish three tiers of pressing research needs in the first thematic area (Table II).

1. The first tier is studies assessing the comparative effectiveness of PCI vs. CABG among the elderly, e.g., patients older than 75 years. Up to 40 percent of people who received revascularization in large registries were 75 years or older, but elderly patients are grossly underrepresented in the existing RCTs. In addition, there is evidence of strong age-by-treatment interaction. In a recent meta-analysis of individual patient data, survival was better with GABG compared with PCI for older patients (p-value for trend was 0.002 across the age categories of younger than 55, between 55 and 65, and older than 65 years). The magnitude of the treatment effect modification was clinically significant, but it is unclear if it generalizes to older patients.
2. The second tier of future research pertains to further study of patients with heart failure and patients with stage 3 or stage 4 renal disease. Although a recent meta-analysis of individual patient data found no significant interaction between heart failure and treatment effect for overall survival (p=0.46), patients with heart failure were excluded from many randomized trials that formed the basis of the meta-analysis. Thus we deem that the interaction of congestive heart failure and treatment choice remains unclear. We identified no analysis of randomized data on patients with chronic kidney disease.
3. The third tier pertains to studying the interaction of diabetic patients and treatment effects. There is already suggestive evidence that survival is better with CABG compared with PCI in diabetics (p=0.014 for treatment by diabetes interaction); such an interaction may be of substantial clinical significance if confirmed by further studies. There are at least two large ongoing trials comparing PCI vs. CABG [FREEDOM (n=2400, NCT00086540) and VACARDS (n=790, NCT00326196)] in diabetic patients whose results should be available within the next 2–3 years. This makes obtaining additional data for diabetics less pressing than for the elderly, heart failure patients, or chronic kidney disease patients.

Finally, we deemed that the subpopulation of women and people who have received PCI in the past represent less pressing priorities than the above, and do not recommend them as priority areas for future research. The previously mentioned meta-analysis of individual patient data found no interaction between sex and treatment effect (p=0.25) for overall survival. The meta-analysis did not report analyses with respect to having a prior revascularization, but key informants suggested that there is little if any evidence for an interaction of treatment with history of revascularization with PCI.

For each of these subpopulations, DES represent a more pressing research need compared to BMS, because they are used more often than BMS in everyday practice, and this trend will most likely continue in the midterm. The above does not mean that future studies should not use BMS. If numbers allow, an option would be to further randomize patients in the PCI arm to BMS vs. DES.

Based on our modeling, new research should inform on the relative effects of treatments on the clinical outcomes of death, myocardial infarction, stroke, and secondarily revascularization in the mid and long term. This thematic area of research is already a mature research field, where many RCTs have been performed already, but not in the subpopulations of interest. In terms of research design, it is probably prudent to first perform reanalyses of existing data, and consider performing new RCTs only if existing data are not applicable to the population of interest, or suggest a subpopulation-by-treatment interaction that is clinically important. Alternatively, one could perform efficient de novo nonrandomized comparative studies and proceed to a de novo RCT only if there is suggestive evidence of an important treatment-by-subgroup interaction. This is because, based on our sample size and power calculations, a de novo RCT would likely require resources comparable to recent large multimillion dollar RCTs. Reanalyses of existing data could be collaborative meta-analyses of individual patient data from prior RCTs or from large observational studies, if the populations of interest are underrepresented in prior RCTs.

### Testing To Inform Treatment Choice (Second Thematic Area)

There is currently not enough data to determine which baseline test or combination of tests may be the best for predicting which patients will have a better response with CABG than with PCI, or vice versa. However, if baseline (pre-revascularization) testing were able to predict long term differential response to PCI or CABG, its effects on patient health would be substantial. For this reason, further elaboration of the ability of testing to identify the optimal intervention for each patient is highly desirable. Based on key informant input, we listed four testing options, either invasive (arteriography) or noninvasive (magnetic resonance or computerized tomography angiography; resting or exercise single photon emission computerized tomography; exercise treadmill testing with or without echocardiography).

There are many different test-and-treat strategies that can be conceived, and it is not possible to compare all of them with randomized studies. The most practical recommendation for future research is to explore the predictive accuracy (sensitivity and specificity) of the tests of interest or combinations thereof by performing cohort studies, case control studies, or by reanalyzing baseline data from existing RCTs (if available). To be clinically useful and informative, such studies should enroll patients representative of those seen in clinical practice, and limit verification and other biases. Such studies should be relatively feasible given the high prevalence of the conditions of interest, the widespread availability of the considered diagnostic technologies, and the fact that most patients treated with PCI or CABG already receive extensive workup before their revascularization.

### Enhancing Patient Participation (Third Thematic Area)

Life expectancy is not the only outcome that matters to patients and those close to them. While the importance of quality of life is generally appreciated by physicians and decisionmakers it is not always clear whether, how, and to which extent it is considered. To facilitate the participation of patients in decisions regarding their treatment, one has to develop and evaluate decision aids.

A suitable study design to elicit patient preferences is a survey of patients, or a qualitative research study that uses focus groups of patients. It is at best unclear whether a study of patient preferences will have a major impact on the remaining research agenda. However, compared to designing and undertaking a new RCT, such studies on patient preferences are quite feasible, and relatively inexpensive.

A suitable study design to develop a decision aid is a qualitative research study that uses focus groups of patients, relatives of patients, and physicians. Based on key informant input, there are no decision aids in routine clinical use. Therefore, the question of evaluating decision aims may be premature.

### Assessing Performance (Fourth Thematic Area)

The fourth thematic area for future research is development of evidence-based performance measures to be used as feedback to health care facilities or practitioners towards improving patient-relevant outcomes. Evidence suggests that establishing performance measures and active monitoring of physician performance has positive impact on the quality of delivered health care. In principle, it should be feasible to identify process-based measures of performance in cardiovascular care, given the existence of multiple interventions with strong support from RCTs in the domain of cardiovascular disease. However, for most chronic diseases, including CAD, it is not possible to use simple “all-or-nothing” measures to quantify optimal care; simple measures are limited to quantifying poor care. Therefore, developing effective evidence-based performance measures will require both qualitative and quantitative research to identify appropriate measures and test their impact on clinical outcomes.

A first step could be the establishment of focus groups of scientists with relevant expertise to propose specific measures based on the current evidence base and analyses of administrative data. Health care professionals as well as participants with expertise in bioinformatics, quality control, or operations research would offer complementary expertise. To inform these focus groups it may be important to conduct analyses of administrative data related to the processes of interest.

The actual evaluation of whether the implementation of a performance monitoring and feedback system could be readily performed in observational studies that measure performance before and after the implementing the monitoring and feedback mechanism. A much stronger design would be a cluster RCT, where one would randomize health care facilities to implement versus not implement the system. However, unless there is substantial infrastructure already in place, such a cluster RCT would not be easy to perform.

## Conclusions

Based on our review of the Stanford CER, input from key informants, newly published and ongoing studies, and our insights from quantitative analyses we identified four thematic areas of future research needs to inform choice between mechanical revascularization procedures in patients with nonacute CAD:^b^

b Because we relied only on key informant input without having the benefit of a thorough evaluation of the literature for the last three thematic areas, and it is possible that the identified evidence gaps have been addressed.

A. [underlined: Comparative effectiveness and safety of PCI vs. CABG]: In the first area, pressing priorities are studies on the comparative effectiveness and safety of DES^c^ vs. CABG in elderly patients (older than 75 years); patients with heart failure or patients with stage 3 or 4 chronic kidney disease; and patients with diabetes. These patient subgroups are often underrepresented in RCTs but are frequently encountered in everyday clinical practice. Further, for the elderly and for diabetics there is suggestive evidence of a subpopulation-by-treatment interaction. An efficient way to address this research need is to capitalize on already existing data by performing meta-analyses of individual participant data from existing RCTs or from large observational studies. An alternative approach is to perform de novo RCTs, especially if existing data are not applicable to the population of interest, or suggest a subpopulation-by-treatment interaction that is clinically important.^d^
  c DES in particular. BMS still represents an important comparator.
  d Alternatively, one could perform efficient de novo nonrandomized comparative studies and proceed to a de novo RCT only if there is suggestive evidence of an important treatment-by-subgroup interaction.
B. [underlined: The role of testing to inform choice of revascularization procedure:] In the second area the priority is to perform studies to assess the ability of invasive (arteriography) and noninvasive tests (MR or CT angiography, resting or exercise SPECT, exercise treadmill testing with or without echocardiography) to predict differential response to PCI or CABG. There are many different test-and-treat strategies that can be conceived, and it is not possible to compare all of them with randomized studies. A practical recommendation for future research is to explore the predictive accuracy of single tests or combinations thereof by performing cohort studies, case control studies, or by reanalyzing baseline data from existing RCTs (if available). To be clinically useful and informative, such studies should enroll patients representative of those seen in clinical practice, and take steps to limit verification bias and other biases.
C. [underlined: Enhancing patient participation:] In the third area the identified research needs pertain to eliciting and measuring patient preferences and facilitating shared decisionmaking by developing and evaluating decision aids. A suitable study design to elicit patient preferences is a survey of patients, or a qualitative research study that uses focus groups of patients. Decision aids can be developed in qualitative research studies that utilize focus groups of patients, relatives of patients, and physicians. Based on key informant input, there are no decision aids in routine clinical use. Therefore, the question of evaluating decision aims may be premature.
D. [underlined: Assessing performance:] Development of evidence-based performance measures, monitoring of practice based on these measures and providing feedback to health care facilities and practitioners can improve revascularization outcomes and may reduce inequalities in provided health care at the national level. The optimal research design to develop reliable process-based measures of performance is not clear. One option is to perform qualitative research using focus groups of health care professionals as well as participants with expertise in quality control or operations research. Evaluating process-based performance measures would be typically performed in large-scope studies that analyze administrative data before and after the implementation of performance monitoring and feedback systems.