# Discussion

## Key Informants

In the current project we used input from a limited group of key informants to identify evidence gaps regarding treatments for stable coronary artery disease amenable to revascularization therapy. We subsequently organized them in four thematic areas, namely comparative effectiveness and safety; use of testing to guide treatment choice; enhancing patient participation and assessing performance. We requested feedback from key informants on how they would prioritize future research needs, but we did not automatically accept their suggestions. We considered their feedback as an additional input along with the Stanford CER, the results of our literature searches, and our insights from focused quantitative analyses. This approach offers a degree of protection from potential conflicts of interest on behalf of the key informants. On the other hand it may have resulted in the omission of real priorities from the final list of research needs. For example, we opted not to prioritize an RCT in women high enough in our list, because there is prior evidence that there is no (detectable) sex-by-treatment interaction (Box 1).

Box 1 Potential methodological questions in developing future research needs documents

What is the optimal role for the key informants? Is their main role to flesh out the evidence gaps or should they be the ones who prioritize the future research needs?
Is a handful of key informants enough to ensure good coverage of the major considerations in the topic? What is the best composition for the key informant group? Is it important that they have a strong methodological background?
Explore the use of simplified models to gain insights for future research. Explore whether the ranking of the importance of different parameters would change if more elaborate models were used instead of simplified ones. Validate or refute our assumption that ranking of the importance of different parameters is relatively robust to bad quality data on costs and utility weights or other model inputs apart from treatment effects.
Explore whether and when simple models can be used to prioritize subpopulations.
Explore the role of network meta-analysis in modeling. Explore empirically the implications of not using consistent estimates of treatment effects in modeling analyses. Explore the implications on incoherence in a network-meta-analysis on modeling results and conclusions.

By its very nature, a document on Future Research Needs should be as specific as feasible in its assessments. Key informant input was invaluable in expanding the list of important evidence gaps, yet expanded lists are more challenging to prioritize. Key informants could not readily identify a specific subpopulation of patients with CAD as the most important priority. While they did provide ranks when they were explicitly asked to do so, their feedback was that, generally, differences between the importance of research needs that received different ranks are not always clear cut. Ideally, a more formal process to engage key informants would be desirable. For example there is evidence that a Delphi process can lead to the development of research recommendations consistent across various stakeholder groups.45 However, there are logistical challenges to routinely performing Delphi processes to prioritize research needs. We believe that any approach to elicit the perceived research needs from key informants should be primarily practical.

The size and composition of the key informant group is also important to discuss (Box 1). We opted to use a small group of six so that we have the opportunity to perform one-to-one interviews. We selected key informants in a nonsystematic way, i.e. we did not use formal sampling methods to select among a large pool of candidates, but aimed for a diverse and representative group that was likely to generate a diverse list of research needs. We invited a medical officer of a funding agency for cardiovascular research, a medical director of a major payor, an interventional cardiologist, a CABG surgeon, a general cardiologist, and a clinical researcher and methodologist with contributions in the field.

We did not invite a patient representative, because we deemed that the patient perspective is not particularly important in the current phase of prioritizing research needs. Unless they have specialized knowledge, patients cannot contribute to identifying priority subpopulations or interventions which represent pressing research needs. An argument in favor of including patient representatives is that they can identify important outcomes that elude the attention of health care professionals. However, there is a long research experience in cardiovascular medicine, and we can reasonably expect that the most important objective and subjective outcomes are already very well known. It may be more fruitful to include patient input when designing a new study, in an effort to augment the list of secondary or tertiary outcomes that the study records.

There is a growing literature in diverse medical fields comparing research priorities as perceived by different stakeholder groups, including researchers and patients. Oliver et al. attempted to develop an evidence based approach for involving “consumers” of research in setting the research agenda for the UK National Health System.46 They noted that the existing literature consisted mostly of descriptive reports “by researchers who were key actors in involving consumers” and indicated that there does not exist a rigorous evidence base for consumer involvement in research agenda setting. O’Donnell et al. surveyed UK-based funders for their approach to involving consumers about what health-related research should be funded.47 They highlighted several issues of concern regarding the difficulty in selecting “appropriate” consumers to provide input, difficulties in understanding the research proposals discussed, possible “distortions” of funding decisions due to consumer biases and uncertainty about how to reconcile discrepancies between professionals’ and consumers assessments of research priorities.47,48

In addition, consideration has to be given to whether the key informants can effectively convey what the important questions are for decisionmakers (patients, clinicians, funders, policy makers). There is only limited evidence that surveys of experts using “nominal group” techniques can produce recommendations for future research that are representative of an entire research community.49 Formal survey methods for eliciting research priorities from research groups have been used in a relatively limited number of diverse fields such as occupational medicine,50,51 hematology,52 nephrology,45 dental medicine,53 and nursing.54,55 However, formal surveys are not practical to perform for the development of future research needs documents.

## Quantitative Analyses Based on Simple Models

We explored whether the use of quantitative analyses offers additional insights. Quantitative analyses require a mathematical model (decision model). It is difficult to develop, debug, and validate a detailed decision model in a short period of time.^a^ Instead, we adopted the operational approach of identifying a published model that is simple and has face validity, and reparameterized it to use information from the evidence report and recent large studies. The advantage of using quantitative methods is that they make explicit all assumptions and data sources used. Further, quantitative methods require a well formulated decisional context, much like a systematic review requires a well formulated answerable clinical question.

a It is may be feasible to develop a decision model de novo if it is sufficiently simple. Even fairly simple representations of clinical dilemmas can provide useful insights.56–58

One insight we obtained during our value of information analysis is that by its very nature, a simple model cannot be used to prioritize subpopulations. To do so, one would have to use a model that includes all the subpopulations of interest, and is appropriately parameterized using subpopulation-by-treatment interactions. It follows that this can be easily done only if the subpopulations of interest are mutually exclusive, which is seldom the case. For example, to prioritize between “diabetics” and “elderly” we would have to explicitly model their intersection (“elderly diabetics” ), and we do not have enough data to do so. This has been described elsewhere as well.59

We used the models as tools to identify where future research is needed the most, albeit indirectly: presumably, one would recommend further research to inform the parameters that are most uncertain in the one-way sensitivity analyses of decision and cost-effectiveness models. This is an atypical use of modeling. We only identify and rank “influential” parameters and stop short of providing insights on treatment choices for different assumptions and circumstances, leaving a lot to be desired. However this is a conscious choice:^b^ Ranking of influential parameters is likely to remain stable even if more elaborate models are used, or if better data are used to populate parameters for which we made simplifying assumptions. In contrast, exact values may change substantially.

b This is admittedly a defensive stance. It is very influenced by the fact that our models are not developed with the same rigor as some of the well-known and elaborate models that are used to analyze clinical decisions; they have not been calibrated using external data; and their predictions have not been validated in external data. They are operational models that are constructed to make use of the summary information obtained from an evidence report, that can still offer broad insights.

An additional insight from the quantitative exercises was that it is imperative to use estimates from network meta-analysis to parameterize models that compare three or more treatment options. Because treatment effect estimates from network meta-analysis are consistent between them, changing the parameterization of the model will always result in identical conclusions, as is logically expected.57 Models that are not parameterized based on consistent estimates from network meta-analysis can give different conclusions under different parameterizations, and can be misleading.60

There is a growing literature on methods and applications of VOI analysis. The UK’s National Institutes for Clinical Excellence routinely includes probabilistic decision and cost effectiveness analyses in their systematic reviews of health technologies and encourage use of VOI analysis to inform research priorities. In the US there is a tendency to avoid of cost-effectiveness analyses,61,62 and this may extend to VOI analyses. VOI analysis is a theoretically motivated method to prioritize future research. Our application of VOI analysis afforded us two insights: First, in view of the relatively large expected costs of medical interventions in the US, estimates of the EVPI and of EVPPI will tend to be much higher compared to those typically reported in other countries. Second, any uncertainty in cost-related parameters is going to influence EVPI estimates substantially especially at low willingness-to-pay thresholds.59 We found that focusing on the EVPPI estimates of non-cost-related subgroups of parameters is more informative for prioritizing future research, because uncertainty around costs is relatively straightforward to reduce.^c^ In our case we focus on the ranking of different groups of parameters according to their EVPPI, but not on the actual EVPPI values. Although we ignore information by focusing on ranks, we also gain by having results that are less likely to change if we modify our models.

c By conducting, for example, surveys of hospitals offering specific procedures or utilizing pre-existing databases.

Our choice of a 10 year horizon for modeling is arbitrary. In VOI analyses it is equivalent to assuming a price “shock” ten years from now, e.g., that a new highly cost-effective treatment will appear after ten years that will render all choices moot.58 Another way to state this is that we simply do not wish to consider a time horizon longer than 10 years as this is already too far into the future, when treatment advances, changes in treatment prices, or changes in the population case mix may drastically change the decisional context. Generally, longer time horizons would tend to increase the actual estimates of the value of future research. Because in our approach we are in relative ranking rather than actual values, considering longer time horizons would most likely not change our insights.

Overall, we believe that modeling is useful for making specific future research recommendations, and not so much for broad-stroke qualitative statements. Ideally, if modeling is contemplated as part of the Future Research Needs documents, provisions should be made early on, during the actual conduct of the CER. This way one would ensure that appropriate data will be identified, appraised and used in the model in a timely manner.57,58

## The Implications of an Incomplete “Intervention Space” in the Decisional Context

An additional insight from our quantitative analyses pertained to the importance of having a well defined decisional context. We already commented on the fact that no revascularization (i.e., use of medical therapy) is a valid clinical option in many if not most patients in whom both PCI and CABG would be considered.13 We excluded medical therapy from our considerations, because evidence on medical therapy was not reviewed in the Stanford CER. Adding medical therapy to the incomplete “intervention space” of our decisional context could dramatically change our suggestions on future research needs. For example, we may have recommended that medical therapy be added to the interventions to be compared in future RCTs. This of course can potentially affect the feasibility of future studies.

Further, in our qualitative approach we did not expand on the comparison between DES and BMS, as our attention was focused on comparisons of PCI methods vs. CABG. After performing quantitative analyses however, it became evident that information is needed on the comparative effectiveness and safety across all three interventions, BMS, DES and CABG. In other words, this means that additional information on BMS vs. DES comparisons may be a valid alternative for future research. It should be noted that different parameterizations of our model could be used to estimate the uncertainty that exists regarding the relative treatment effects of DES and BMS.