# Conclusion

Based on our review of the Stanford CER, input from key informants, newly published and ongoing studies and our insights from quantitative analyses we identified three thematic areas of future research needs to inform choice between mechanical revascularization procedures in patients with nonacute CAD: comparative effectiveness and safety; use of testing to guide treatment choice; and elicitation of patient preferences, development of decision aids and evidence-based performance measures.

In the first area, pressing priorities are analyses of individual participant data or new RCTs on the comparative effectiveness and safety of DES vs. CABG in elderly patients (older than 75 years); patients with heart failure or patients with stage 3 or 4 chronic kidney disease; and patients with diabetes.

An additional priority is to perform studies of the ability of invasive (arteriography) and non invasive tests (MRA or CTA, resting or exercise SPECT, exercise treadmill testing with or without echocardiography) to predict differential response to PCI or CABG. Pending such data it is unclear whether RCTs are needed to compare testing to guide choice of revascularization vs. no testing.

It is relatively inexpensive to perform studies to enhance understanding of patient preferences. It is also important to explore the development of decision support aids as well as to develop evidence-based performance measures.